# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
ANCOVA: analysis of covariance
CER: comparative effectiveness review
CI: confidence interval
CPAP: continuous positive airway pressure
DL: Dersimonian-Laird
IPD: individual patient-level data
KH: Knapp-Hartung
MD: mean difference
ML: maximum likelihood
PE: permutation
PL: profile likelihood
RCT: randomized controlled clinical trial
REML: restricted maximum likelihood
SMD: standardized mean difference
TMS: transcranial magnetic stimulation