# Results

A total of eight interviews were conducted with U.S. organizations representing: guideline developers (n=3), health care providers (n=3), research funder (n=1), and non-commercial payers/insurers (n=1). Six of eight KIs were clinical providers; two produced guidelines for professional organizations, two represented health systems, one was a funder, and one represented a non-commercial payer. Two KIs were non-clinical; one produced guidelines for a professional group and the other represented a health system. All KIs routinely commissioned and used systematic reviews. There was varied representation with respect to knowledge and use of rapid review products: three KIs were involved in producing rapid review products, two KIs used rapid review products, and three KIs were unaware of or had no experience using rapid review products.

## Users' Perspectives on Important Characteristics of Reviews

KIs reported what they consider the most important characteristics of review products for their use; the themes that emerged are presented in Table 1 and are related to methods, source of the review, relationship between producer and user, clinical significance, and the recency of the review. The most commonly reported review characteristics deemed critical were: (1) the review was from a reliable source, i.e., conducted by experienced reviewers from an established research organization (all KIs); (2) the review addressed clinically relevant questions (all KIs); and (3) there was a relationship between the user and producer of the review (7 of the 8 KIs; 1 KI did not discuss). KIs felt that the key questions were often the most important part of the review. If the key questions do not address what the user needs, the review is not very useful. Further, the relationship between the user and producer ensures that the review is more usable. Other important review characteristics that were noted include: addressed questions of clinical (and not just statistical) significance, was recent, and used sound methodology (all items were noted by 4 KIs and not mentioned by 4 KIs).

Table 1 Users' perspectives on important characteristics of reviews

Element | Theme | Sample Quotes [type of end-user]
Overall Review Characteristics
Methods | Important that sound methods are used in developing review | “..adherence to good standards of evidence evaluation is really critical, so that probably matters more to me than anything” [provider]
Source | Trust review products from reliable sources | “If it came from a place that we trust then we would have more confidence in using it than if it was just arbitrarily out there from somebody who had done it once.” [guideline developer] “the source is always really important, knowing that someone is evaluating the evidence in a rigorous way, the way that we do and the way the evidence based practice centers do means a lot” [provider]
Relationship between producer/user | Important to establish relationship with user up front | “… the quality that we've had in the reviews when they have that connection up front is significantly different…I think it also helps build trust in how the evidence is being done.” [guideline developer] “…I think it's incredibly important for the guideline developers to be involved from day one.” [guideline developer]
Clinical significance | Reviews should include considerations of clinical importance not just statistical significance | “…ultimately, the clinical aspect is important. There is sometimes a gap between the statistical significance versus what's clinically significant important.” [guideline developer]
Recency | Important that a report is recent. A gap search is sometimes done. | “We're usually hoping we find something within the last two to three years” [guideline developer] “We're certainly willing to do the bridge look search to make sure that there hasn't been something big that's come up that might adjust the estimated treatment effects” [guideline developer]
Key questions | The framing of the question can be the most important aspect of a review It is important that the key questions address what the end-user needs, including clinical outcomes and consideration of benefits and harms Narrowing the scope of the key questions can be problematic | “…the thing that I find most helpful in this approach to evidence always is the framing of the question” [provider] “…we want to make sure that the questions that were addressed are what the guideline developers interested in terms of just plain old clinical outcomes” [guideline developer] “When I've used some other Rapid Reviews, when they narrow the scope they probably at least half the time completely miss the mark of the question we want answered. Keeping it a little bit broader would be something that I would not sacrifice…” [payer]

## Users' Perspectives on Review Methods

Table 2 presents themes and sample quotes regarding KIs' perspectives of individual components of a review. KIs felt the following were very important: quality rating of studies (noted by 7 KIs; not mentioned by 1 KI), data tables (including characteristics of included studies) (4 KIs; not mentioned by 4 KIs), strength of evidence assessment (5 KIs; not mentioned by 3 KIs), and summary tables of results and conclusions (3 KIs; not mentioned by 5 KIs). One KI (research funder) mentioned that specific recommendations regarding future research needs were important for use in research development and future funding.

Table 2 Users' perspectives on review methods

Element | Theme^*^ | Sample Quotes [type of end-user]
Specific Review Components
Literature search | It is okay to limit the search by database, journal, year, etc. as long as it is scientifically justified | “I'd probably be more comfortable with selecting top 20 [journals]…and just do the evidence review using those.” [guideline developer] “I would not expect things like looking for unpublished literature.” [payer] “you…probably you get 90% or 95% of the evidence with 20% to 30% of the searching” [provider]
Abstract/full text screening | It is okay to have single review of abstracts and full text | “To me that [single review] would be acceptable.” [research funder] “I think implicitly in these kinds of rapid reviews…you're going to do a combination of looking at existing reviews so that will help catch stuff that you might otherwise miss with single review.” [provider]
Quality assessment | Some assessment of the quality of the literature is needed | “I think that [quality assessment] should be included.” [payer] “it's important that we probably would want some level of comment on that [quality assessment]” [provider]
Data tables/extraction | Evidence tables are useful | “I think the most important part of an evidence review is always going to be the evidence tables” [guideline developer] “one part that we use a lot are of course the extraction tables” [guideline developer]
Strength of evidence | Strength of evidence is important | “That [strength of evidence grading] would be very important.” [payer] “The strength of the evidence I always find valuable as well.” [provider]
Summary tables | Summary tables or ways to present the results/conclusions in an accessible format are useful | “A lot of times you'll do good summary tables, and that's probably where I would look…” [payer] “The work development teams in our clinical programs are more concerned with what's the summary of the evidence.” [provider]
Future research recommendations | Future research recommendations are helpful for research development | “…what are the future research recommendations…99.9% of the systematic reviews all concluded more research is needed, so focus on exactly what are they recommending.” [research funder]

* Comments in bold represent most acceptable trade-offs

The most commonly reported acceptable trade-offs to increase efficiencies were in the literature search (all 6 KIs who mentioned literature search agreed that limits such as date or language were acceptable) and abstract and full text review (among 5 KIs who discussed this point, 4 agreed that single review was acceptable and 1 agreed depending on the expertise of the individual doing the review). The majority of KIs were willing to have shortcuts made in these areas in exchange for shorter timelines. One KI (guideline developer) elaborated and noted that these trade-offs would be acceptable in order to have something more readily available to directly inform clinical care rather than waiting for a comprehensive answer. This same KI noted the trade-off in terms of doing a single, comprehensive review versus multiple rapid products in the same amount of time.

## Uses of Rapid Products

KIs reported a variety of potential uses for rapid products and standard systematic reviews (Table 3). Several KIs stated that the evidence inventory (3 KIs; guideline developers, provider organization) and rapid response (4 KIs; guideline developers, research funder, provider organization) would not be useful for their purposes, while other KIs considered evidence inventories or rapid responses useful in certain cases including for new topics, to understand the depth and/or breadth of existing evidence/available literature, for restricted local use, or for clinicians who are already familiar with the literature in a topic area. One theme that emerged is that when KIs saw utility in the rapid products, these were more often interim products (or “placeholders”) to inform downstream investigation (e.g., whether to move forward with a full review or a guideline, direction for future research/funding); the rapid products were not typically useful for “end-point” decisions (especially the evidence inventory and rapid response). Moreover, some KIs commented that the level of detail available in the evidence inventory and rapid response was not sufficient for decisionmaking; most KIs indicated that analysis/synthesis and quality/strength of evidence was important to this end. Some KIs (guideline developer, provider organizations) noted that an evidence inventory and rapid response were products that the end-users could easily create on their own.

Table 3 Uses of rapid products and standard systematic reviews

Use | Evidence Inventory | Rapid Response | Rapid Review | Systematic Review
For broad topic areas/population issues | | | | ×
To inform research agenda | | | | ×
For in-depth understanding of a topic area | | | | ×
For guideline or recommendation development | | | × | ×
For guideline/recommendation updates or new issues subsequent to a guideline/recommendation | | | × | ×
For coverage decisions | | | × | ×
For organizational or policy change | | | × | ×
For implementation | | | × | ×
For quick decisions | | | ×
When no previous SR or guidance exists | | | ×
For “hot” or timely topics | × | ×
In area with limited literature | × | ×
To understand depth and/or breadth of evidence e.g., evidence maps | × | ×
To clarify whether a review is already available | × | ×
To ignite/catalyze change or challenge the status quo | × | ×

All but one KI indicated that they could see a use for a rapid review, in particular for guideline development (particularly for narrow topics), policy decisions when a quick turn-around is needed, decisionmaking in nuanced clinical settings and for practicing clinicians, and coverage decisions. Most KIs felt that standard SRs cannot be used for quick decisions, unless they already exist, in which case they may need a bridge search. Oftentimes a bridge search is needed even for recent SRs, because they take so long to complete that there is often a gap in the literature search by the time it is published. KIs noted some factors to be considered when using a rapid review including that the review needs to: a) have quality methods or be from a reliable source, and b) address the specific questions/clinical outcomes of interest. Generally, a traditional systematic review is preferred but in cases where none exists, KIs are willing to accept rapid review for shorter turnaround. Further, KIs understand that there may be limitations to rapid reviews, but they are willing to accept these for a quick turnaround. One KI (provider) noted that it is never possible to eliminate uncertainty, so it just needs to be taken into consideration when using different review products. One KI (guideline developer) felt that the rapid review was limited in terms of the spectrum of benefits and harms needed for their decisionmaking purposes. Further, rapid reviews may not be helpful if they do not provide sufficient detail with respect to important subgroups.

Another theme that emerged is that rapid responses and rapid reviews may be more relevant for issues (often narrow questions) that arise within the clinical setting specific to a health system (where it may be more feasible to narrow the scope), or when interest is more on implementation (e.g., tailoring the evidence to a given region/setting). Conversely, KIs felt that broad/national guidelines more often need a full SR. The following is one KI's comment highlighting this perspective (guideline developer):

“So that's the dichotomy to me is that there are people working on implementation and what's going to happen out in our system of care delivery; and there are people working on trying to make sure that what we're saying is the right thing to be doing and there's a tension between that. We've often talked about the struggle to balance rigor with efficiency and so the operationally oriented folks are willing to take a risk on the absolute correctness and the answer in order to do something and to do it reliably across the delivery system where the more traditional EBM people and guideline people would really rather take the time to make sure they know that they've got the right answer.”

Many KIs emphasized that an evidence review is just one part of the decisionmaking process. There are many other factors considered, including cost and feasibility.

## Themes About Review Products

Our analysis of interviews about rapid products with end-users of AHRQ EPC systematic reviews identified the following themes:

- Trust was the primary issue that arose in the context of how end-users valued a review, and in particular whether they would rely on a rapid product. Trust was associated with a producer that the KIs knew or that had a positive reputation (e.g., established legacy of activity). Other aspects that contributed to trust in a product or producer was how the material was presented (e.g., consistent approach, attention to detail) and clear/transparent specification of methodological details (even if some limitations were applied). KIs stressed that trust is built through active engagement with the end-users. Methodological alterations (e.g., single review at multiple steps of the systematic review process) appear to be secondary to the trust established through consistent products and active end-user engagement. Further, if end-users trusted the source, they were willing to overlook occasional mistakes or oversights.
- KIs stressed the relevance of the key questions, noting that if the questions did not directly address the specific end-user's needs, the review was of little or no value. This applied to rapid products as well as full systematic reviews; however, this was one of the major limitations of a rapid product - the frequent need to narrow the scope of the key questions , or restrict the number or types of outcomes, as a means to increase efficiencies. One particular situation where rapid products were considered limited was where more detailed analysis of subgroups was needed to inform specific coverage, clinical, or policy decisions. End-users spoke about needing to conduct supplemental searches and analyses themselves in order to fill this gap.
- Maintaining a close working relationship between the end-user and the review producer was considered important in order to ensure that the key questions and their components respond to the end-user's needs and purpose. Without a close and ongoing relationship there is a concern that the actual report becomes distant from the original questions.
- Several KIs found the strength of evidence and evidence tables to be essential and often the most valuable parts of the reports. End-users liked to see the outcome data, methodological quality, and strength of evidence summarized in a readable and readily accessible form (e.g., formats that “front-load” the information you need with additional “information that you can go to if you have specific questions”).
- The ability to easily change or reverse a decision (or change your mind) may be one distinction or hallmark of when a rapid product may be useful. For example, KIs expressed that a full systematic review is more often necessary for clinical practice guidelines, broad application of the evidence (e.g., “change the direction of the organization on a very important topic”), or macro topics (e.g., population-level implementation). Conversely, a rapid product may be sufficient: for decisions being made on a local basis (e.g., point-of-care clinical decisions, nuanced clinical situations, local coverage decisions) where there is not the same level of scrutiny; for “in the moment sort of decisions”; to act as an update for a previous comprehensive guideline or address an issue that comes up secondary or subsequent to a guideline; or, to get a general sense of the literature or scale of the issue. These latter cases may be used to inform or stimulate discussion or challenge the status quo.
- Related to the above issue, KIs commented on the risk that a rapid product might give the wrong answer and indicated that reviews “narrow uncertainty but never eliminate it;” moreover, “there's always a chance you're going to miss something.” The implication of being wrong was considered to depend on the stakes (e.g., ability to change a decision). One KI commented that getting something wrong is “not isolated to a rapid review;” for example, some decisions have been made based on large trials published in high impact journals which are subsequently contradicted by new evidence—“it happens in all kinds of areas in the medical literature.” In general, uncertainty seemed more acceptable for local, system-based decisions versus national guidelines: “it's the tradeoff of how long do you want to wait to be sure that you have the absolutely right answer versus get this knowledge into the field where people might be able to start applying it.”
- KIs commented on the fact that there is generally more than the evidence of benefits and harms to consider when making a decision; therefore, rapid products provide one source of information in the context of other considerations for decision-making. Due to these other factors, there may be less perceived risk of using a rapid product (e.g., in terms of the answer being ‘wrong’ or level of concern that information might be missed). These other factors include context (e.g., viewpoints of the public and clinicians), the burden of disease and population affected (e.g., vulnerable populations), and costs (e.g., common and inexpensive vs. rare and expensive). In fact for the payers, costs can “be a deal breaker”.
- A final theme that emerged was that it is the responsibility of reviewers to help users understand potential ramifications of streamlined methods, as end-users may not be aware of the specific steps and accepted methodological approaches. Moreover, as mentioned above, the end-users appear less concerned with methodological alterations so long as the product comes from a reliable source and addresses their questions of interest. One KI reported using the AMSTAR tool to assess whether a review is trustworthy.