# References

1 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions Version 5.1. 0. [updated March 2011]. Cochrane Collaboration. Cochrane Collaboration. 2012.
2 Ganann R, Ciliska D, Thomas H. Expediting systematic reviews: methods and implications of rapid reviews. Implementation Science. 2010;5(1):56. [pmid: 20642853].
3 Sampson M, Shojania KG, Garritty C, et al. Systematic reviews can be produced and published faster. Journal of clinical epidemiology. 2008;61(6):531-6. [pmid: 18471656].
4 Chandler J, Churchill R, Higgins JP, et al. Methodological standards for the conduct of near Cochrane Intervention Reviews Cochrane Collaboration. Unit CE. December. 2013. http://editorial-unit.cochrane.org/mecir.
5 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews Agency for Healthcare Research and Quality. Publication No. 10(14)-EHC063-EF. Rockville, MD. Quality AfHRa. January. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Polisena J, Garritty C, Umscheid CA, et al. Rapid Review Summit: an overview and initiation of a research agenda. Systematic reviews. 2015;4(1):1-6. [pmid: 25554246].
7 Cochrane Innovations. Cochrane Response - the new Rapid Review from Cochrane. 2014. http://www.cochrane.org/about-us/cochrane-innovations. June 2015.
8 Hartling L, Guise J, Kato E, et al. EPC Methods: An Exploration of Methods and Context for the Production of Rapid Reviews. Agency for Healthcare Research and Quality (US). February. 2015:2015.
9 Guise J-M, Chang C, Viswanathan M, et al. Systematic reviews of complex multicomponent health care interventions. Rockville (MD). Agency for Healthcare Research and Quality (US). March. 2014.
10 Morse JM, Field PA. Qualitative research methods for health professionals. 2nd ed. Thousand Oaks, CA. SAGE Publications, Inc. 1995.
11 Canadian Agency for Drugs in Technologies in Health. Acetylsalicylic acid for venous thromboembolism prophylaxis: an update of clinical evidence CADTH. CADTH. August. 15. 2014.
12 ECRI Institute. Knee-length versus Thigh-length Compression Devices for Deep Venous Thrombosis ECRI Institute. Institute E. March. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Umscheid CA, Mitchell MD. Intermittent pneumatic compression devices for venous thromboembolism prophylaxis. University of Pennsylvania Health System Center for Evidence-based Practice. 2009.
14 Jayakumar KL, Lavenberg JA, Mitchell MD, et al. Evidence synthesis activities of a hospital evidence-based practice center and impact on hospital decision making. Journal of hospital medicine. 2015.
15 Sobieraj DM, Coleman CI, Tongbram V, et al. Venous thromboembolism prophylaxis in orthopedic surgery. Comparative Effectiveness Review No. 49. (Prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center under Contract No. 290-2007-10067-I.) AHRQ Publication No. 12-EHC020-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012.
16 Featherstone RM, Dryden DM, Foisy M, et al. Advancing knowledge of rapid reviews: an analysis of results, conclusions and recommendations from published review articles examining rapid reviews. Systematic reviews. April. 17. 2015;4(50).
17 Oxman AD, Schünemann HJ, Fretheim A. Improving the use of research evidence in guideline development: 8. Synthesis and presentation of evidence. Health Research Policy and Systems. 2006;4(1):20. [pmid: 17147809].
18 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. Journal of clinical epidemiology. 2009;62(10):1013-20. [pmid: 19230606].
19 Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ: British Medical Journal. 1994;309(6964):1286. [pmid: 7718048].
20 Giustini D, Boulos MNK. Google Scholar is not enough to be used alone for systematic reviews. Online journal of public health informatics. 2013;5(2):214. [pmid: 23923099].
21 Moher D, Klassen TP, Schulz KF, et al. What contributions do languages other than English make on the results of meta-analyses?. Journal of clinical epidemiology. 2000;53(9):964-72. [pmid: 11004423].
22 Selph SS, Ginsburg AD, Chou R. Impact of contacting study authors to obtain additional data for systematic reviews: diagnostic accuracy studies for hepatic fibrosis. Systematic reviews. 2014;3(1):1-9. [pmid: 24383422].
23 Bushman BJ, Wells GL. Narrative impressions of literature: The availability bias and the corrective properties of meta-analytic approaches. Personality and Social Psychology Bulletin. 2001;27(9):1123-30.
24 Horsley T, Dingwall O, Sampson M. Checking reference lists to find additional studies for systematic reviews. Cochrane Database of Systematic Reviews 2011. Art. No.: MR000026. [doi: 10.1002/14651858.MR000026.pub2]. 2011;(8).
25 Watt A, Cameron A, Sturm L, et al. Rapid reviews versus full systematic reviews: an inventory of current methods and practice in health technology assessment. International Journal of Technology Assessment in Health Care. 2008;24(02):133-9. [pmid: 18400114].
26 Watt A, Cameron A, Sturm L, et al. Rapid versus full systematic reviews: validity in clinical practice?. ANZ journal of surgery. 2008;78(11):1037-40. [pmid: 18959712].
27 Danz MS, Hempel S, Lim Y-W, et al. Incorporating evidence review into quality improvement: meeting the needs of innovators. BMJ quality & safety. 2013. bmjqs-2012-001722.
28 ECRI Institute. AHRQ Health Care Horizon Scanning System Protocol and Operations Manual: January 2013 Revision Agency for Healthcare Research and Quality. Rockville, MD. Quality AfHRa. 2013.