# Purpose of This Report

The overall aim of this project was to understand perspectives on rapid products (specifically, evidence inventories, rapid responses, and rapid reviews as defined in Figure 1). Our objectives were to:

1. Determine what makes end-users trust and value an evidence synthesis, including (but not limited to) extent of synthesis, extent of information (e.g., level of detail), specific pieces of information (e.g., which elements are particularly useful), formatting/presentation of information, organization that produced the report (and end-user relationship with that organization), and methods used to conduct the synthesis. We were also interested in whether this varies by the nature of the decision being made.
2. Determine end-user impressions of different rapid products with a focus on acceptability and usability (not necessarily validity). Determine their impressions with respect to: strengths and limitations, trade-offs (what approaches could be altered to increase efficiencies, what are they willing to accept), and risks (in terms of the answer being ‘wrong’; level of concern that information might be missed).
3. Determine where/when/how end-users might use rapid review products and whether this varies by the nature of the decision being made. Guiding questions included:
  a. If you had a rapid product, would it be useful to you and in what context?
  b. If you had a time dependent decision, what are you confident using, knowing that different products may give different answers?