# Methods

## General Approach

A workgroup of members from EPCs, the Scientific Resource Center (SRC), and AHRQ participated in twice monthly workgroup teleconference calls over the course of 10 months to discuss project direction and scope, assign and coordinate tasks, collect and analyze data, and discuss and edit draft documents.9

We undertook a qualitative study of AHRQ end-user perspectives of rapid products. Qualitative methods allow researchers to elicit perspectives from participants and identify themes. Further, qualitative interviews allow the interviewer to obtain the information sought, and, due to their open-ended nature, they also provide the opportunity for the interviewer to probe for greater depth and clarity and for the respondent to elaborate or provide examples to illustrate concepts and perspectives.10

## Key Informant Selection and Interviews

To ensure the findings were most relevant to the AHRQ EPC Program, and due to logistical constraints, we decided to focus on frequent end-users of AHRQ EPC reviews. We then identified different types of organizations that may use EPC reviews: research funders, payers/health insurers, health care provider organizations, and societies/associations (e.g., that produce guidelines). We identified 12 organizations representing these different stakeholders. We approached individuals from these organizations and invited them to participate in an interview. The invitation to participate in the interviews is in Appendix A. Prior to the interviews, each KI completed an “EPC Conflict of Interest Disclosure Form”; no disclosed conflicts precluded participation. All KIs were familiar with or had used EPC reports (i.e., traditional systematic reviews); some also had experience with rapid products.

The same workgroup member (J-MG) conducted all interviews between January and March of 2015 using a semi-structured interview guide designed to elicit a multi-faceted understanding of perceived value and uses of rapid products. Prior to the call, participants were sent the interview questions and samples of products (evidence inventory, rapid response, rapid review, and full EPC evidence report) that would be discussed. The semi-structured interviews were conducted by telephone, lasted for approximately one hour, and were attended by at least 2 additional workgroup members. All interviews were digitally recorded and transcribed verbatim. At the outset of each call, the KI was asked for their permission to have the call recorded (with the intent that recordings were for the purpose of data analysis only). Further, we asked KIs for permission to use quotes from the interviews but assured them that the quotes would not be attached to any specific individual. All KIs agreed to these conditions. We have not listed the names of the KIs or the organizations they represent in order to preserve confidentiality due to the sample size.

## Interview Guide

The workgroup developed the interview guide through a review and discussion of multiple iterations. As our KIs were end-users of AHRQ reports, we were first interested in how they had used EPC reports and what they valued in the reports produced through the EPC program (e.g., what made the reports trustworthy or reliable, what components were most critical to informing their decisions). Next, we were interested in their impressions of the different rapid products (evidence inventory, rapid response, rapid review—see Figure 1), as well as whether they would consider any of the rapid products useful and in what context, e.g., for specific decisionmaking needs. We were particularly interested in: a) what trade-offs they would be willing to accept to increase efficiencies in the review production, and b) what risks they perceived might be incurred with new approaches (e.g., inaccurate findings, missing studies). The final interview guide appears in Appendix B.

## Sample Rapid Products

From an initial list of 11 recently completed (within the past 2 to 3 years) EPC systematic reviews on topics considered to be of general interest, we selected 4 topics: venous thromboembolism, fecal DNA testing, pressure ulcers, and methicillin-resistant staphylococcus aureus. We then searched to identify rapid products on these topics through agencies we knew to produce rapid products. We found the most and broadest range of rapid products for venous thromboembolism and chose among these to represent the three rapid products to share with the KIs. The Evidence Inventory was produced by the Canadian Agency for Drugs and Technologies in Health,11 the Rapid Response was produced by ECRI Institute,12 and the Rapid Review was produced by the Penn Medicine Center for Evidence-based Practice.13, 14 The full EPC systematic review on the same topic is available at: effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1145.^15^

## Data Analysis

Transcripts were analyzed using content analysis with NVivo™ software by two research assistants with training in qualitative analyses. Two investigators with qualitative experience independently reviewed all transcripts and verified themes and subthemes. To ensure reliability of the coding structure, all themes and subthemes were reviewed with the larger multi-disciplinary workgroup.