# Introduction

## Background

Rapid reviews are a form of evidence synthesis that may provide more timely information for decision making compared with standard systematic reviews. Systematic reviews are defined as “a review of a clearly formulated question(s) that uses systematic and explicit methods to identify, select, and critically appraise relevant research, and to collect and analyze data from the studies that are included in the review.”1 While systematic reviews are comprehensive, they can take on average 1 to 2 years to complete2, 3 and involve a substantial amount of resources to produce according to current standards.4 While standards are endorsed by numerous groups that commission, produce, and publish systematic reviews, many of the specific steps are not supported by strong empiric evidence (e.g., extent of search, dual study selection, dual data extraction, etc.).1, 5 In contrast, rapid reviews “are literature reviews that use methods to accelerate or streamline traditional systematic review processes” in order to meet the needs and timelines of the end-users (e.g., “government policymakers, health care institutions, health professionals, and patient associations”).2 Several recent activities highlight the increasing interest in rapid reviews and their methodologies, including the Canadian Agency for Drugs and Technologies in Health (CADTH) Rapid Review Summit (https://www.cadth.ca/cadth-summit-series),6 Cochrane Innovations' Rapid Response Program,7 and registration of a rapid review methods group with The Cochrane Collaboration.

As part of this effort, in 2013 a white paper produced through the Evidence-based Practice Center (EPC) Program of the Agency for Healthcare Research and Quality (AHRQ) explored the range of products that are considered rapid. The AHRQ EPC program produces comprehensive systematic reviews, as well as other products such as Technical Briefs, Horizon Scanning, and Topic Triage documents which incorporate elements of rapid products. The white paper examined 36 different rapid products from 20 organizations worldwide and interviewed 18 producers of rapid products.8 A careful analysis of the 36 rapid products led to a taxonomy that allows a practical classification of these products according to the extent of synthesis (Figure 1): (1) “inventories” list what evidence is available, and other contextual information needed to make decisions, but do not synthesize the evidence or present summaries or conclusions; (2) “rapid responses” present the end-user with an answer based on the best available evidence (usually guidelines or SRs), but do not attempt to formally synthesize the evidence into conclusions; (3) “rapid reviews” perform a synthesis (qualitative and/or quantitative) to provide an answer about the direction of evidence and possibly the strength of evidence; (4) “automated approaches” use databases of extracted study elements and programming to generate meta-analyses in response to user-defined queries.

Figure 1 Taxonomy of rapid products8

A figure titled 'Taxonomy of rapid products.' This figure represents an outline for the practical application of 36 rapid products according to the extent of their synthesis.The first box reads “evidence inventories.” To its right there is a box that offers 3 bulleted guidelines which read, “List what evidence is available, and often other contextual information needed for making decisions.” “Do not synthesize the evidence or present summaries of conclusions.” “Generally systematic and comprehensive: therefore, can provide a useful first step for decisions about coverage or purchase, in particular whether further research is warranted.” Below the first box, is box 2 that reads “rapid response.” To its right there is a box that offeres 3 bulleted guidelines which read,“Evaluate the literature to present the end-user with an answer based on the best available evidence (usually guidelines or systematic reviews).” “Do not attempt to formally synthesize the evidence into a conclusion.” “More likely to describe clinicians among end-users.” Below the second box is box 3 that reads “rapid review.” To its right there is a box that offers 3 bulleted guidelines which read, “Perform a synthesis (qualitative, quantitative or both) to provide the end-user with a conclusive answer about the direction of evidence and possibly the strength of evidence.” “Conclusion may be hedged, but it is still a synthesized statement that could be compared with a systematic review.” “Generally able to meet time constraints by limiting the scope, are somewhat less comprehensive in their data sources, use fewer quality controls, and the synthesis is usually qualitative.” Below the third box is box 4 which reads “automated approaches.” To its right there is a box that offers 1 bullet of guidance that reads, “A new and intriguing approach to providing rapid evidence support.”

One of the key findings of the white paper was the observation, based on interviews with 18 producers of rapid reviews, that one of the biggest differences of rapid products compared with standard systematic reviews was the relationship with the end-user. The paper noted that “rapid products are often conducted to help a specific end-user make a specific decision in an identified timeframe; therefore, the reviewers need to make decisions about what they can provide in the time allowed.” To further understand end-user perspectives on rapid products, we undertook the present work to understand the acceptability of different approaches to rapid products (based on our taxonomy) to end-users, as well as the context in which particular products may be useful.