# Key Informants

In conducting this research, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought perspectives of the Key Informants on rapid products. Key Informants were not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The names of individual Key Informants (and the organizations they represent) who participated in the research described in this report are not listed to preserve confidentiality.