# Discussion

Our findings add to what was previously known about the variety of available rapid review products and distinguishes potential uses by AHRQ end-users. We specifically asked key informants about three different rapid review types (evidence inventory, rapid response, and rapid review). Our interviews suggest that each product type could prove useful under specific circumstances. In particular, evidence inventories and rapid responses may be useful decisionmaking tools for “hot” or timely topics, for areas with limited literature, or to understand the extent of available evidence. True rapid reviews, in contrast, could be used by AHRQ end-users for instances when quick decisions are required or for implementation decisions.

The qualitative interviews identified a number of critical aspects relevant to using rapid review products. Our findings confirm that end-users build trust with review producers and suggest that rapid review products may be more or less acceptable to decisionmakers based on the established reputation of producers. This places the responsibility for the reliability and validity of the product in the hand of the producers. Producers need to ensure that rapid products use transparent methods that communicate potential risks to end-users.16 In addition, producers should be aware of the potential harm a misleading conclusion in a rapid product could have on their reputation.17

Our interviews indicated that end-users may accept trade-offs in review methods, such as limiting the literature search and conducting single screening of abstracts and full text. For the scientific systematic review community, eliminating key procedures meant to reduce reviewer errors and bias represents an important variation from the methods used in most current AHRQ EPC products, which follow standard systematic review methodology.18 Empirical research on systematic review approaches has concentrated on identifying the incremental validity of systematic review methods,19-24 or the validity of the end product (for example, comparing the conclusions reached in rapid reviews vs. systematic reviews).25, 26 However, such empirical research is limited, and further research is needed to fully understand the impact of changes to standard systematic review methods (e.g., screening and data abstraction in duplicate by two independent reviewers rather than by a single reviewer, or by a single reviewer with verification) and other steps used to expedite evidence reviews.2

According to our key informants, other characteristics of the review product also appear to significantly contribute to the usability of the product, such as quality assessment of included studies, the use of evidence and summary tables, strength of evidence assessments, and future research recommendations. The trade-off of reducing or removing these aspects of reviews to gain efficiencies may result in the review being less valued by the end-user.

Our findings also reaffirm the value of the relationship between review producers and end-users, particularly for the development of key questions that the review aims to answer.27 The interviews suggested that an interactive and ongoing relationship ensures that the product meets end-user's needs.

With respect to the different types of rapid products, KIs were more likely to consider them useful if they had previous direct experience using them. The following observations were made for the specific rapid review products:

Figure 2 Taxonomy of rapid products: Evidence Inventory8

This figure is titled: Taxonomy of rapid products: Evidence Inventory. It is a box that offers 3 bulleted guidelines which read, “List what evidence is available, and often other contextual information needed for making decisions.” “Do not synthesize the evidence or present summaries of conclusions.” “Generally systematic and comprehensive: therefore, can provide a useful first step for decisions about coverage or purchase, in particular whether further research is warranted.”

Evidence Inventory: Although some of the KIs saw value in this product, it was generally not considered sufficient to inform decisionmaking because it did not “give an answer to the question” or a synopsis of the evidence. Some KIs indicated that an evidence inventory may be useful to stimulate discussion, to challenge the status quo, or to get a sense of the literature when there is a pressing concern. These situations were typically in the context of a hospital system, particularly in the case of internal barriers to implementation (e.g., the literature shows alternative approaches).

Figure 3 Taxonomy of rapid products: Rapid Response8

This figure is titled: Taxonomy of rapid products: Rapid Response. It is a box that offers 3 bulleted guidelines which read,“Evaluate the literature to present the end-user with an answer based on the best available evidence (usually guidelines or systematic reviews).” “Do not attempt to formally synthesize the evidence into a conclusion.” “More likely to describe clinicians among end-users.”

Rapid Response: Again, few KIs found this product to be sufficient for their decisionmaking needs although they did prefer this to an evidence inventory as it provided some synopsis of the literature. A perceived use for a rapid response was to validate the need for future research or an evidence synthesis (e.g., identify the volume of research in a given (sometimes broad) area and whether or not there is consistency in terms of benefits, and for some local clinical or systems-level decisions).

Figure 4 Taxonomy of rapid products: Rapid Review8

This figure is titled: Taxonomy of rapid products: Rapid Review. It is a box that offers 3 bulleted guidelines which read, “Perform a synthesis (qualitative, quantitative or both) to provide the end-user with a conclusive answer about the direction of evidence and possibly the strength of evidence.” “Conclusion may be hedged, but it is still a synthesized statement that could be compared with a systematic review.” “Generally able to meet time constraints by limiting the scope, are somewhat less comprehensive in their data sources, use fewer quality controls, and the synthesis is usually qualitative.”

Rapid Review: Many of the KIs liked the rapid review and generally considered this to be acceptable when a traditional systematic review is unavailable. Most types of end-users considered the rapid review to be useful. While the guideline developers generally wanted something more comprehensive and detailed, they felt rapid reviews may be used for guidelines on narrow topics, updates of guidelines, or for new issues that arise subsequent to a guideline or recommendation. Other end-users (e.g., payers/insurers) were less concerned about comprehensiveness. Positive aspects of the rapid review included its conciseness, clear presentation, and a focus on existing syntheses and high quality studies. This was considered useful for policy decisions that were time-dependent. It was noted that rapid reviews may not be useful if the findings are subtle, or when the literature is inconsistent and there is a need for more detailed (and comprehensive) evaluation to tease out the results (e.g., reasons for inconsistency/heterogeneity).

## Implications for the EPC Program

AHRQ's EPCs are recognized as leaders in conducting comprehensive systematic reviews that influence clinical practice, shape health policy, and assist stakeholders in health care decision making. The typical process for producing a systematic review within the EPC Program follows a number of steps including topic nomination, topic triage, topic refinement, and completion of the full review, and can take as long as two years. Hence, reviews cannot be commissioned to provide evidence to support decisions that need to be made urgently.8 Further, due to the prolonged process and multiple stakeholders involved, the end product is sometimes considered too long, dense, or not ideally focused for a particular stakeholder. Based on the previous work cited, we envisioned that rapid review products (or some of the methods and/or approaches they employ) may be relevant to the EPC Program; however, an important step was to assess the end-user perspectives on different rapid review products, and the acceptability of different approaches to support their decision making needs.

While based on a small sample, this project suggests that some discussion within the EPC program may be warranted to explore how we can modify our approach to meet end-users' needs. This may entail more flexibility in the range of products and/or approaches; however, careful consideration in offering rapid products is needed given that some rapid products may have limited relevance, e.g., only informs a particular decision by a particular stakeholder. The project also highlighted the importance of spending adequate time and effort on the front end of the process (i.e., when engaging the partner or critical stakeholders). It may be that an end-user would accept and prefer a rapid product over a full review given a shorter timeframe in which they need to make a quick decision. The current topic refinement process within the EPC Program aims to ensure that key questions are relevant and meet end-user needs; however, this process can be considered lengthy (i.e., up to 6 months), particularly given that the full review can take up to an additional year to produce. Some aspects of rapid review methodology are already part of existing EPC processes (e.g., methods used in topic triage to determine which topics should go forward). Further, some aspects of rapid review products are already part of existing EPC products (e.g., Technical Briefs do not provide a synthesis of the evidence and focus more on the systematic identification of available literature and pertinent research issues; Horizon Scanning aims to identify new, or new uses of existing, drugs and technologies to inform investments in comparative effectiveness research).28 End-users may value access to interim EPC products, such as topic triage, intended to inform the full review. Currently, there is no central clearinghouse of rapid products. Future efforts to create a searchable online database of rapid products could be valuable to both end-users and producers, and may avoid unnecessary duplication; however, caveats about what these different products offer are needed to ensure that end-users understand their purpose and potential limitations.

## Strengths and Limitations

We followed sound qualitative methodology in eliciting perspectives from different types of users and in identifying themes. However, our small sample size means that results may not be representative of all end-users and we cannot be sure that the themes reached saturation. This is especially true in considering whether there are differences in the perspectives across and between types of users. The hypotheses generated from this work need further evaluation.

We chose to interview frequent and known users of AHRQ products. It may be that infrequent users or more varied audiences would have different perspectives. It could be, for instance, that new or different users would find more or less value in rapid review products. Eliciting views from additional audiences may also help in understanding obstacles or benefits to using rapid reviews. However, current AHRQ users provide a critical perspective as they are knowledgeable about systematic review methodology, have a high standard for evidence synthesis, and may be considered the most likely audience for any AHRQ rapid review products.

## Future Directions

Our small sample size meant that we could not make definitive statements in comparing the needs and values of different end-users. Further, there are other perspectives we did not collect, including those from front line clinicians, patients, and infrequent users of AHRQ products. Conducting interviews with a larger number of more diverse users would allow differences to be teased out and enable the evaluation of hypotheses identified in this work.

We were also unable to identify specific tradeoffs that would be acceptable to end-users. A more structured survey of end-users may provide more information about trade-offs. These types of questions could elucidate what would be acceptable in terms of time or other resource trade-offs for the inclusion of a specific review methodology or characteristic. Under what circumstances, for what questions, would end-users trust a rapid review product?

Ideally, future studies would also move beyond hypothesis generation to empirical testing. A possible design is the completion of a systematic review and a rapid review product on the same question. Ultimately, we would want to know how long it took to produce each product, if these different review products were more or less useful for end users in informing decisions, and, most importantly, if those decisions would be different depending on the product used.

Empirical research on the impact of streamlining specific methodological approaches is essential given the finding that changes to methodological approaches appear to be acceptable to end users as long as trust is established through consistent products and active end-user engagement, and there is clear communication by producers about methods and the potential ramifications of streamlined methods.

Finally, this and our previous work on rapid reviews have identified a tremendous wealth of information contained within these products that could be useful to stakeholders beyond those who commissioned the specific reports. However, there is no central repository for rapid products. Many are not published in traditional peer-reviewed sources, indexed in bibliographic databases, or digitally archived. While some are publically available on the websites of review producers, others are only available upon request or subscription. Discussion among the community of rapid review producers to explore the potential for a central repository is warranted.

## Conclusions

This work provides insight into the perspectives of AHRQ evidence synthesis end-users, highlighting as important: the credibility of the review producer, relevance of key questions, and close working relationship between the end-user and review producer. This work also identifies review characteristics that are considered essential for decisionmaking, some acceptable methodological trade-offs, and potential uses of rapid review products.