# Invitation to Key Informants

Dear [Key Informant],

We are conducting a project on end-user perspectives of rapid reviews. This is an extension of a white paper we produced last year that examined methods and guidance for conducting rapid reviews. As part of this Agency for Healthcare Research and Quality (AHRQ) funded project, we are having discussions with thought leaders in the field who use AHRQ Evidence-based Practice Center (EPC) reviews.

Because of your experience as an end-user of EPC reviews, we would like to schedule a time to speak with you. If you or your organization does not use EPC reviews, please let us know. Also, please let us know if there is a different person in your organization that you think we should contact instead.

Your participation would involve a 60-minute individual interview. In this discussion we hope to learn your perceptions of evidence syntheses currently produced through the EPC Program, what aspects of them are helpful for your decision-making, and whether there are trade-offs in methods or comprehensiveness you are willing to make for different decisions and to meet different timelines.

If you are able to participate, please respond to our doodle poll with your availability at [link to doodle poll]

If you are unable to make any of the above times, please let us know and we may be able to arrange another meeting time.

Please confirm whether or not you will be able to participate in this project by [Date, 2014].

Thank you for your consideration. If you have any questions, or would like additional information, please contact Pua Motu'apuaka at Makalapua.Motu'apuaka@va.gov or 503.220.8262 x52367.

Sincerely,

- Jeanne-Marie Guise, M.D., M.P.H.
  Associate Director
  Scientific Resource Center for the AHRQ Effective Health Care Program

Sent on behalf of Jeanne-Marie Guise by the AHRQ Scientific Resource Center