# Results

## Guidance Summary

Overall, about half of the systematic review organizations provided some direction on the use of existing systematic reviews. Table 2 shows the list of organizations that were hand searched. A check mark under the area of guidance denotes a comment on the use of existing systematic reviews, though not necessarily detailed guidance. Listed organizations with no check marks are organizations for which guidance on the use of existing systematic reviews was not found.

Table 2 Available guidance/comment on the use of existing systematic reviews

Organizations Hand Searched | Guidance Areas
Organizations Hand Searched | Locating and Defining Appropriate Use | Assessing Relevance | Assessing Review Quality | Determining Use: Scanning References | Determining Use: Search Strategy | Determining Use: Risk of Bias Assessment | Determining Use: Data Abstraction | Determining Use: Synthesis | Methods/Results Reporting
AHRQ Evidence-based Practice Center Program (EPC program) Methods Guide for Effectiveness and Comparative Effectiveness Reviews2 | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Reporting the Findings of Updated Systematic Reviews of Comparative Effectiveness6 | | | | | | | | | ✓
Canadian Agency for Drugs and Technology in Health (CADTH) Guidelines for Authors of CADTH Health Technology Assessment Reports7
Cochrane Collaboration Cochrane Handbook for Systematic Reviews of Interventions8 | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Danish Centre for Health Technology Assessment (DACEHTA) Health Technology Assessment Handbook9 | ✓ | ✓ | | | | ✓
European Collaboration for Health Technology Assessment (ECHTA) Best Practice in Undertaking and Reporting Health Technology Assessments10 | ✓ | ✓ | | | | ✓
Health Technology Assessment International
Institute of Medicine Finding What Works in Health Care: Standards for Systematic Reviews11
Institute for Quality and Efficiency in Health Care (IQWiG) General Methods12 | ✓ | | ✓ | | | | | | ✓
National Institute for Health and Care Excellence (NICE) The Guidelines Manual, Draft for Consultation13 | ✓ | | ✓ | ✓
York Centre for Reviews and Dissemination: Systematic Reviews (CRD) CRD's Guidance for Undertaking Reviews in Healthcare14

## Evidence-based Practice Center Discussions

### Overall Themes

- EPCs most commonly used existing reviews as a source of relevant literature and as context for the introduction or discussion section of reviews
- Existing reviews were most useful when Key Questions and/or PICOTS-SD (population, intervention, comparator, outcome, time frame, setting, and study design) matched or when they addressed a specific subquestion of the new review
- Using existing reviews was often more resource intensive than completing a de novo review
- EPCs often did not trust aspects of reviews conducted by others
- When relevant and rigorous, incorporating prior reviews into the review being undertaken by the EPC was clearly valuable in at least two instances: (1) allowing larger scope of the review being undertaken without additional resources; (2) or when an providing summarized evidence when an in depth review of primary literature would not be feasible (e.g., existing reviews provide of individual patient data analysis or include hundreds of trials, supplemented by author-provided data)

EPCs have used existing reviews in various ways, most commonly as a source of relevant literature, allowing them to reduce the extent of searching to locate primary literature or to check completeness of primary literature search strategies. Additionally, prior reviews are often used as context for the introduction or discussion sections of a report. At a minimum, most EPC members feel that it is necessary to acknowledge other systematic reviews and to put the findings of the current review into the context of other systematic reviews, particularly in the case of disagreements or controversy.

EPC members noted that methods determining when and how to use an existing review are highly dependent on the topic and scope of the new report. There are certain instances when it may be most feasible to use an existing review as evidence in a new report. For example, existing reviews are more likely to be used as evidence for a new report when the Key Questions match and when the review questions are concerned primarily with one or a few well-measured outcomes; existing systematic reviews are fruitful to incorporate to answer contextual questions that do not demand a full systematic review, but are important for decisionmakers when considering the formal evidence base. Conversely, EPC members indicated there are other instances when it would not make sense to use an existing review, such as when there are few studies on a given topic or when there are multiple conflicting systematic reviews. When incorporating existing reviews into a new or updated review, EPC members most often described qualitative or narrative incorporation of the existing reviews, noting that quantitative combination of findings (without going back to all primary studies) is more difficult and potentially introduces error, and thus is less commonly done.

EPC members varied in their thoughts and experiences about the efficiency of using existing reviews. Most thought that, although theoretically this process should result in efficiency gains, challenges that arise when trying to use reviews often negate any increased efficiency. These challenges arise from the need to understand and qualify the methods for existing systematic reviews as intensively as primary studies. Thus, EPC members often described experiences where using a prior systematic review resulted in as or more intensive resource requirements as completing a de novo review of primary literature. A particular concern were instances in which stakeholders who nominated the review requested a de novo review after seeing the results of incorporation of existing reviews. It is hard to estimate how much work will be required to clarify the relevance or quality of existing systematic reviews, since effort depends on the volume of existing systematic reviews, as well as issues specific to the match between existing reviews and the review being undertaken; these include whether the Key Questions are an exact match or how the existing systematic review authors approached important methods, such as strength of evidence grading or risk of bias assessment. In a number of cases, EPC members described eventually having to conduct much of the process from scratch in spite of completing the additional step of in-depth examination of existing reviews. EPC members voiced concern about using this process based on the potential (although often unrealized) benefit of efficiency, while running an unclear risk of error or reduced quality from relying on unverifiable work from others. Additionally, EPC members described discomfort with the lack of guidance in this area, noting inconsistency across EPCs in how this process is approached and hesitancy to engage in such a process without explicit direction in the EPC Methods Guide.

Although EPC members felt that it was often difficult to gain efficiency using existing reviews, they acknowledged other potential benefits to this process. Some described that including existing reviews sometimes enables them to cover a wider range of questions and elements of questions (as denoted by PICOTS) when existing systematic reviews address important aspects of new review Key Questions. EPC members suggested that this breadth is often desirable, but may not be possible if independent review of the primary literature is required due to time and resource limitations. Similarly, important evidence to answer some Key Questions may include individual patient data meta-analyses or data from a large number of U.S. Food and Drug Administration trials, representing work from systematic reviewers that would be very difficult or impossible to reproduce. Finally, many commented on the benefit of providing context from existing reviews even if the reviews are not incorporated beyond the introductory and discussion sections of a new review. In fact, putting a new review's findings in the context of existing systematic reviews, particularly when they have conflicting findings, is an important aspect of producing a useful scientific report.

Overall, EPC members noted that more guidance is needed for using existing reviews. Most felt that detailed, specific, step-by-step guidance may not be feasible but that some further articulation of important areas to consider, with clear worked examples, would be helpful. Commonly highlighted areas in need of additional guidance include—

1. Providing principles or criteria for when a new review by an EPC adds value to a field with many existing reviews
2. Providing templates or advisory considerations for construction of evidence tables for reviews combining primary and secondary (systematic review-level) evidence
3. Reporting guidelines for clearly communicating the methods for locating, selecting, and deciding how best to utilize existing systematic reviews
4. Unbiased methods for selecting reviews to incorporate from among multiple existing reviews
5. Guidance on unbiased methods for incorporating selected portions of a review
6. Qualitative and quantitative methods for summarizing bodies of evidence that include a systematic review as the only or as one source of evidence
7. More robust means for quality rating of existing systematic reviews (beyond AMSTAR [A Measurement Tool To Assess Systematic Reviews])
8. Specific methods to grade strength of evidence for bodies of evidence that include a systematic review as the only or as one source of evidence.

Guidance addressing the first item listed may fall more within the topic refinement stage of the EPC program's current processes. In this paper we assume that the EPC has been assigned a new review and is considering incorporating existing reviews. The remaining challenges in using existing reviews are discussed below as they fall within each of the methodological areas presented in Figure 1. A summary of the existing guidance for each area is presented along with an assessment of future guidance needs.

## Methodological Areas: Assessment of Areas of Need

### Locating Existing Systematic Reviews

#### Available Guidance

Several organizations present guidance on locating existing systematic reviews, including the EPC program and the Cochrane Collaboration. These groups recommend using specific databases and search filters to aid in locating existing systematic reviews. Commonly recommended databases include: Database of Abstracts of Reviews of Effects (DARE), Cochrane Database of Systematic Reviews (CDSR), Health Technology Assessment Database, MEDLINE and Embase. Some organizations promote limiting searches for existing systematic reviews to selected sources (e.g., CDSR), with the idea that these systematic reviews would be expected to meet sufficient quality standards.

#### Evidence-based Practice Center Discussions

EPC members expressed concerns about locating reviews based on very limited sources, for example only searching for EPC or Cochrane reviews. Some EPC members were uncomfortable with any type of selective search instead of doing a broader, if not comprehensive, search for existing systematic reviews. However, other EPC members felt it could be appropriate to selectively use one or two earlier reviews without having to review all of the available prior reviews, pointing out that the scientific rationale and purpose in conducting a systematic search for existing systematic reviews is different than when searching for primary studies. Currently there is a lack of consensus and limited guidance concerning how to adequately locate and transparently select and use only a subset of reviews.

#### Assessment

Current EPC guidance on locating existing systematic reviews states that EPCs should conduct a targeted search of a higher yield database which includes output from the EPC program, MEDLINE's Top 120 Index Medicus Journals, Health Technology Assessments, CDSR and DARE. EPC program guidance suggests that identifying existing systematic reviews may be done separately or be completed as part of the broad de novo search for primary literature to answer Key Questions. EPC members shared concern about the extensive effort that may be required to search for and locate all reviews and assess their quality. Instead, given the purpose of locating pre-existing systematic reviews, the ideal search might locate only highly relevant, well-done, very recent existing systematic reviews that are more likely to allow the current reviewer to leverage the prior work. Some members proposed that future guidance further limit the search for earlier reviews to sources that may have greater likelihood of identifying higher quality and better reported reviews, such as the EPC and Cochrane databases.

### Assessing Relevance

#### Available Guidance

Several organizations present guidance on assessing the relevance of existing systematic reviews. European Collaboration for Health Technology Assessment (ECHTA) and Danish Centre for Health Technology Assessment (DACEHTA) provide general guidance for assessing the relevance of all literature, but no guidance specific to existing reviews. Cochrane provides guidance for assessing the relevance of existing systematic reviews for use in an overview of reviews and specifically recommends that reviewers consider if a review is up to date (up to date is not defined in this context, but for Cochrane reviews is considered as a review with a search conducted within last 2 years). The EPC program provides EPCs with some guidance for assessing whether an existing review can answer Key Questions or subquestions of a review. The EPC program recommends consideration of how recently the review's primary literature search ended and how well the PICOTS-SD elements are reported and match with the current review, noting that partially relevant reviews may be useful for background or checking references. As described in Appendix B, specific steps recommended in EPC guidance include conducting an initial screening for relevance while considering the timeliness of the review's literature search. In the second stage of screening, the review's PICOTS-SD elements should be compared with those in the new review protocol for relevance. If these elements are poorly reported, the new reviewers should not consider incorporating the existing review. If a review is outdated, but otherwise on point, an update of the search could be done.

#### Evidence-based Practice Center Discussions

EPC members raised concerns about deciding which existing reviews, if any, to use in a review, especially in situations when many reviews of varying quality or scope are available. It can often be difficult to find reviews that match on all elements of question. Still existing reviews may be sufficiently similar to consider using, although criteria for all situations are not easy to define. Thus, determining which reviews are “close enough” is inherently subjective and can be time-consuming.

#### Assessment

Guidance exists for assessing the relevance of existing reviews, for conducting overviews of reviews and for integrating existing reviews into a new review. Even so, EPC members expressed concerns about selecting which reviews to use when many are available. They reported rarely finding reviews that match directly for all elements of questions and therefore must consider the strengths and weaknesses of the available options. A clearer understanding of the factors (such as clinical area, review purpose, volume of literature, type of review) that have been correlated with successful (and unsuccessful) attempts to incorporate prior systematic reviews might be helpful to EPCs in targeting their future work.

### Assessing Review Quality

#### Available Guidance

Guidance is available on assessing the overall quality of systematic reviews. ECHTA and DACEHTA provide general guidance for assessing the quality of all literature, but do not specifically address assessing the quality of systematic reviews. In contrast, Institute for Quality and Efficiency in Health Care (IQWiG) and York Centre for Reviews and Dissemination (CRD) present guidance on assessing the quality of systematic reviews and recommend the use of a quality rating tool or checklist such as Oxman and Guyatt's quality index or the AMSTAR Instrument.4, 5 National Institute for Health and Care Excellence (NICE) suggests using these reviews as evidence in developing a new guideline if they are up-to-date, have been assessed as high quality using the NICE methodology checklist for systematic reviews,15 and include the accompanying evidence statements and evidence tables. EPC guidance recommends using AMSTAR as a starting point for quality assessment and supplementing as deemed appropriate for specific reviews. The Cochrane Collaboration is currently developing a new tool to assess risk of bias in systematic reviews. In addition, the Institute of Medicine report “Finding What Works in Health Care: Standards for Systematic Reviews” may provide the basis for the development of instruments to assess quality of systematic reviews.11

#### Evidence-based Practice Center Discussions

EPC members raised concerns about using AMSTAR to rate the quality of reviews, specifically, as to how accurate AMSTAR is in differentiating between poorer quality and better quality reviews. This is important since EPCs generally agreed that evidence from existing reviews should only be used if the review can be relied upon to substitute for the high-quality methods espoused by the EPC program. A suggestion was raised for a minimum standard of quality to be set for earlier reviews that are included as evidence in new reviews.

#### Assessment

Guidance is available for quality rating of reviews with available tools and checklists (e.g., Oxman and Guyatt, AMSTAR, NICE).4, 15, 16 However, EPC members noted that these quality assessment tools have limitations. Further, it is important to remember that these instruments do not assess the quality of primary evidence, which must be taken into consideration. More explicit consideration of the quality rating approaches available for systematic reviews, and empiric evidence to support these, would help EPCs in their efforts to qualify existing systematic reviews for use in their own work.

### Determining Appropriate Use for Relevant Existing Systematic Reviews: Scanning References

#### Available Guidance

Cochrane, the EPC program, and CRD provide guidance on scanning the reference lists of existing systematic reviews. These organizations suggest scanning the reference lists of existing reviews as a supplementary method to find relevant studies for a new systematic review. Prior EPC program guidance suggested cross-checking primary studies from one or more existing systematic reviews to confirm adequacy of primary searches or to help select the most comprehensive existing review for incorporation.

#### Evidence-based Practice Center Discussions

Overall, most EPC members had experience using existing reviews for scanning references for relevant articles. No major concerns over the use of existing reviews in this manner were presented.

#### Assessment

Some guidance is available for using existing reviews as a potential source of relevant articles for a new review. As noted below, incorporating search results from a prior systematic review to substitute for some or all of the new review's search efforts is different from simply scanning references as an additional source of information to support other de novo efforts. More commonly, the latter occurs (i.e., reference lists from existing reviews are used to augment or check comprehensiveness of the search yield used in the current review). In general, EPC members felt comfortable using existing reviews as a way to identify possible additional articles for a review. Thus, this does not appear to be an area where future guidance is needed except for the general methodological question of when this type of hand-searching has reached saturation (i.e., when no further relevant studies are being identified and searching may stop).

### Determining Use: Search Strategy and Results of Existing Searches

#### Available Guidance

Cochrane and the EPC program provide guidance on using the search strategy from existing reviews. The EPC program recommends using part or all of the search strategy from an existing review, particularly in the case of updating. The EPC program also indicates when it is acceptable to incorporate results of searches from existing systematic reviews to locate all primary studies; that is, when the search methods (e.g., search strategy, inclusion/exclusion criteria, literature screening methods) are consistent with EPC program methods for finding evidence. The EPC program recommends supplementing primary studies from the existing systematic review by performing bridge searches whenever the search date for the existing review ended more than 1 year earlier than searches for the new review are being conducted.2 Data from primary studies gathered through these combined search efforts are then abstracted, followed by de novo analysis and synthesis of data. Cochrane recommends utilizing information about search strategies from existing reviews and guidelines when possible in a new review, but does not address using search results in entirety.

#### Evidence-based Practice Center Discussions

EPC members reported sometimes using the search strategy from an existing review, particularly when search strategies are reviewed and approved as robust and current by their medical librarians. EPCs also mentioned that, once they have determined it is methodologically appropriate to incorporate an existing review's search results, they go beyond simply including the primary studies from the existing search. Instead, they check the primary studies against their inclusion/exclusion criteria, and some go further by also checking all studies from the excluded studies table in the previous systematic review, particularly in cases where there are slight differences in the questions or eligibility criteria.

#### Assessment

Some guidance is available on using the search strategy and search results from existing reviews. The EPC program provides some guidance for when to trust a search strategy from a prior review. Given the developing practice of medical librarians requesting peer review searching for their de novo search strategies, medical librarian review prior to incorporating an existing search strategy could be warranted. EPC members reported varying experiences with using search strategies in their entirety. Existing guidance related to when and how to incorporate the results of previous search strategies is relatively robust in the current EPC guidance; incorporation of existing search results is also the most common way EPCs report incorporating existing systematic reviews into their work. Further guidance should be based on empiric evidence to establish whether any additional value is added by: (1) considering included studies from more than one existing systematic review; and (2) considering excluded studies from the previous systematic review upon which the search results are being based.

### Determining Use: Data Abstraction

#### Available Guidance

Cochrane, NICE, and the EPC program provide guidance on using the data abstraction from existing reviews. When using existing reviews in a new guideline, NICE recommends creating new evidence summaries but using and directly referencing the original evidence tables from the prior review. For an overview of reviews, Cochrane guidance recommends using the abstracted data presented in the existing reviews and seeking additional information from the authors of systematic reviews or from primary study authors only if necessary. Though there is ongoing work in this area by EPCs such as the Systematic Review Data Repository (SRDR) project which will likely affect how abstracted data are used in the future, current guidance from the EPC program suggests using data abstraction tables from an existing review only if the methods used are deemed to be high quality and are consistent with the EPC program methods for abstracting evidence.

#### Evidence-based Practice Center Discussions

Most EPC members had concerns over whether or not data abstracted from an existing review are trustworthy, comprehensive, or accurate. Additionally, it was often reported that people tend to have to go back and abstract at least some data themselves from the primary studies due to slightly different outcomes, missing data or improper abstraction. This is particularly true when access to full evidence tables is limited, as can be the case with some peer-reviewed manuscripts. For any data abstraction that is incorporated, spot-checking for quality assurance was recommended, though there was no consensus on the minimum level required.

#### Assessment

Some guidance is available for using the data abstraction from existing reviews. However, there are still issues to be resolved when considering using abstracted data from an existing review. Additionally, ongoing work such as the SRDR project could obviate the need for separate guidance if pre-abstracted, high-quality data become available for many reviews. At the least, tools like SRDR will result in the need for updated guidance which incorporates such new data resources for reviewers. Guidance should specifically address various possible data abstraction scenarios. One such example is guidance related to including all versus only some of the abstracted data from an existing review. Because of different review scopes, PICOTS-SD, quality criteria of included studies, etc., systematic reviewers may determine that they will only need to use a portion of the data included in an existing review. Conversely, systematic reviewers may determine the need for adding to existing abstracted data either by abstracting additional data from previously included studies or by adding entirely new studies. Oftentimes, such a decision is based on factors such as more recent search date, additional search terms, and/or different PICOTS-SDs. All of these factors may result in more included studies which would need to be added to the existing abstracted data. Finally, as noted in the included EPC discussion themes, systematic reviewers are often concerned about the trustworthiness or accuracy of abstracted data. Therefore, guidance is needed to establish consistent, reliable methods for conducting data checking or confirming the abstracted data to assure accuracy of the previously reported results. This could allow reviewers to incorporate existing data abstractions, except in circumstances of unreliability revealed by the data checking.

### Determining Use: Study-Level Risk of Bias Assessments

#### Available Guidance

Guidance is available on assessing the risk of bias of individual studies, though little guidance specifically addresses how to incorporate this information from existing reviews into a new systematic review. Cochrane recommends conducting quality assessments of evidence for all outcomes addressed in an overview of reviews and evaluating the quality assessment judgments from existing reviews to ensure consistency among included reviews. If an existing review does not include a quality assessment, Cochrane recommends performing a quality assessment of the primary studies. The EPC program also recommends study-specific risk of bias assessment for all included studies, with components of the assessment based on study design.

#### Evidence-based Practice Center Discussions

EPC members noted that quality assessment of a systematic review to determine appropriateness for inclusion in a new systematic review is not sufficient to represent the quality of individual studies included in the existing review. When a review is incorporated as more than a source of primary studies, it raises a number of issues about how to proceed in terms of quality rating. EPC members expressed strong concerns about relying on the risk of bias assessments from prior reviews conducted by other reviewers; in particular, risk of bias assessments are known to be poorly reproducible, and often lack transparency and rationale for ratings. No guidance is available on how to integrate information from reviews that do not have risk of bias assessments, or used risk of bias assessment tools different from those used by the EPC. Overwhelmingly, EPC members felt that the primary studies included in an earlier review needed to be quality rated in some way that is sufficiently consistent with other primary studies included in the new review. Even if existing reviews include risk of bias assessments, an overarching theme from the discussion with EPC members was that it may be difficult for reviewers to trust the reliability of other reviewers' risk of bias assessments. Some EPC members felt that you may be able to trust particular sources (e.g., Cochrane or EPCs) using particular risk of bias assessment tools.

#### Assessment

Guidance is readily available for assessing the risk of bias of primary studies with currently available tools and checklists (e.g., Cochrane, EPC program).2, 8, 17, 18 However, the lack of guidance about when to accept or when to repeat such assessments when conducted by others as part of prior reviews was of particular concern to EPCs. Other issues of concern for EPCs include how to handle risk of bias assessment from prior reviews that are based on different tools from those used in a new review. Lack of clear guidance in this area is a barrier since the possible need to assess risk of bias for all primary studies introduces resource demands that reduce the likelihood of efficiency from incorporating existing systematic reviews.

### Determining Use: Synthesis, Including Strength of Evidence Assessment

#### Available Guidance

Cochrane and the EPC program provide some guidance on using the synthesis from existing systematic reviews. Cochrane provides guidance on using prior synthesis in an update of a review and in an overview of reviews. In an update, Cochrane recommends to rerun the synthesis if data from new studies are found. In an overview of reviews, Cochrane recommends relying on the previous analysis as much as possible and only reanalyzing data if necessary (e.g., if different populations or subgroups are analyzed in different reviews). The EPC program recommends incorporating an existing review in its entirety, including evidence summaries, only if it is high quality, the Key Questions are very similar to the new review's questions, and the methods used are consistent with EPC program methods. However, current EPC program guidance does not explicitly address methods for incorporating prior syntheses. The EPC program does address dealing with discordant results from existing reviews and recommends making an effort to determine reasons for the disagreements both as part of the new review planning and in discussion of its findings. At the review planning stage, uncertainty of which discrepant results to trust can provide a strong rationale for conducting a de novo review. No current guidance is available on performing strength of evidence assessments for systematic reviews, particularly as one component of a larger body of evidence answering a Key Question.

#### Evidence-based Practice Center Discussions

Most EPC members had concerns over how and if you can trust a prior review and whether or not you can trust the data synthesis. Particularly, the lack of guidance available for assessing strength of evidence when integrating an existing systematic review poses challenges. Despite current guidance, EPC members had additional concerns about how to deal with discordant results from reviews.

#### Assessment

Limited guidance is available on using the synthesis from existing reviews and this is an area that EPC members struggle with when considering using existing reviews. EPCs particularly struggle when asked to assess overall strength of evidence for mixed bodies of evidence (i.e., those representing both primary studies and prior systematic reviews). The difficulty is compounded by the need for different guidance, depending on the circumstances surrounding the prior review(s) and the current review. We identified four scenarios that might require different guidance as to how the synthesis may be used from an existing review: (1) up to date and has a meta-analysis; (2) up to date and presents a narrative summary; (3) not up to date and has a meta-analysis; (4) not up to date and presents a narrative summary. These scenarios obviously apply only when one or more existing reviews are being included in a new review based on meeting certain criteria (e.g., scope of Key Questions, PICOTS, and quality).

### Methods and Results Reporting

#### Available Guidance

IQWiG, NICE, Cochrane and the EPC program present guidance on reporting results when utilizing existing reviews. The Annals of Internal Medicine has also published methodological reporting requirements for authors.19 For a benefit assessment based on systematic reviews, IQWiG recommends summarizing the results from existing reviews in tables and noting any differences in results between reviews. In a guideline document using existing reviews, NICE recommends referencing evidence tables from existing guidelines with a direct link to the source and creating new recommendations based on the evidence. Cochrane provides guidance on how to present information in an update of a review, including how to highlight information from new studies. When integrating existing reviews, the EPC program recommends including a summary table of included systematic reviews, including an assessment of the overlap in primary research between reviews. Additionally, the EPC program recommends justifying the use of existing reviews and commenting on advantages and disadvantages of using existing reviews in the discussion session. In an update of a review, the EPC program recommends explicitly showing what has changed from the previous report.

#### Evidence-based Practice Center Discussions

EPC members had concerns about how to show evidence from reviews, including how to highlight the primary evidence when using a prior review. Challenges have surfaced when users of EPC reports are unable to identify specific details about primary studies because they have been included as a part of a systematic review instead of highlighted individually. Some EPC members have presented varying levels of detail based on how they used existing reviews but had no guidance on the best approaches. Other EPC members have tabled existing systematic reviews and pulled out elements for discussion, even when the existing reviews are not otherwise integrated into a report.

#### Assessment

While some guidance is available for how to report the methods to locate and decide how to use an existing review, issues still may arise when reporting results from existing reviews. Specifically, it can be difficult to highlight primary studies or isolate results from individual studies when integrating results from existing reviews. Guidance is needed on the level of detail needed on all aspects, such as how new data where incorporated into evidence tables. Future examination of various approaches recommended by different groups and development of a set of templates with worked examples could be very useful.