# References

1 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Int Med. 2008;148(10):776-82. [pmid: 18490690].
2 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. April. 2012. http://effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication-Draft_20120523.pdf. April 23, 2013.
3 Fordis M. Observations in Translating CERs: Informing Report and Translation Product Development, Example 2.1. Evidence-based Practice Centers IV Inaugural Meeting. 2012 December 12. Rockville, MD.
4 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-8. [pmid: 1834807].
5 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7(1):10. [pmid: 17302989].
6 Newberry S, Shekelle P, Motala V. Reporting the Findings of Updated Systematic Reviews of Comparative Effectiveness: How Do Users Want To View New Information?. Agency for Healthcare Research and Quality. AHRQ Publication No. 13-EHC093-EF. Rockville, MD. May. 2013. http://effectivehealthcare.ahrq.gov/ehc/products/532/1497/reporting-findings-viewing-new-info-white-paper-130516.pdf. May 17, 2013.
7 Canadian Agency for Drugs and Technologies in Health. Guidelines for Authors of CADTH Health Technology Assessment Reports. CADTH. ISBN 1-894620-87-9 (online). Canada. 2003.
8 Higgins J, Green S. Cochrane handbook for systematic reviews of interventions. The Cochrane Collaboration. 2011.
9 Kristensen F, Sigmund H. Health Technology Assessment Handbook Danish Centre for Health Technology Assessment. National Board of Health Copenhagen. 2007.
10 Busse R, Orvain J, Velasco M, et al. Best practice in undertaking and reporting health technology assessments. Int J Technol Assess Health Care. 2002;18(2):361-422. [pmid: 12053427].
11 Eden J, Levit L, Berg A, et al. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC. National Academies Press. 2011.
12 Institute for Quality and Efficiency in Health Care. General Methods Institute for Quality and Efficiency in Health Care. Germany. September. 23. 2011. https://www.iqwig.de/download/General_Methods_4-0.pdf. March 22, 2013.
13 National Institute for Health and Care Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2012.
14 Centre for Reviews and Dissemination. Systematic Reviews: CRD's Guidance for Undertaking Reviews in Health Care. Centre for Reviews and Dissemination, University of York. 2009. www.york.ac.uk/inst/crd/pdf/Systematic_Reviews.pdf. May 17, 2013.
15 National Institute for Health and Care Excellence. The Social Guidance Manual. National Institute for Health and Care Excellence. London. 2013. http://publications.nice.org.uk/the-social-care-guidance-manual-pmg10/about-this-manual#acknowledgements. April 23, 2013.
16 Oxman AD. Checklists for review articles. BMJ. 1994;309(6955):648. [pmid: 8086990].
17 Balshem H, Helfand M, Schünemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401-6. [pmid: 21208779].
18 Higgins JP, Altman DG, Gøtzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
19 Cornell JE, Laine C. The science and art of deduction: complex systematic overviews. Ann Int Med. 2008;148(10):786-8. [pmid: 18490692].