# Methods

## Guidance Summary

Documents and Web sites from systematic review organizations were manually searched for available guidance on the use of existing systematic reviews. Where available, relevant guidance was extracted and summarized for each of the methodological steps in Figure 1.

## Evidence-based Practice Center Discussions

Individual workgroup members held discussions with EPC members including EPC directors, associate directors, and project managers. The goals of the discussions were to gather insights from the experiences of EPCs in integrating existing systematic reviews and to identify common issues and challenges and potential solutions. Individual workgroup members conducted discussions with 15 EPC members representing 10 of 11 EPCs. A list of participating EPC members can be found in Appendix A. Major themes from the interviews were identified by workgroup members through review of discussion notes. These themes were compared with the existing guidance to identify areas of overlap and need.

## Assessment of Areas of Need

Workgroup members assessed the sufficiency of currently available guidance based on the needs expressed by EPCs. Through individual and group deliberation, the workgroup determined which methodological areas for the use of existing systematic reviews need additional guidance. For each area where additional guidance is needed, the workgroup generated suggestions for how to develop this guidance.