# Introduction

In the context of exponential increases in the numbers of systematic reviews published, constrained resources for new reviews, and the increase in the need to update reviews, there is an urgent need for detailed specification of methods to explicitly and transparently integrate existing reviews into systematic reviews. A number of years ago, researchers from several Evidence-based Practice Centers (EPCs) recognized that reviewers were increasingly faced with decisions about whether and how to incorporate existing systematic reviews into new systematic reviews. This group collaborated to develop guidance for the use of existing systematic reviews.1 As part of the EPC Methods Guide, a workgroup was subsequently formed by the Agency for Healthcare Research and Quality (AHRQ) on the same topic, and guidance that generally reflected the prior work was issued.2

The guidance we provided in the EPC Methods Guide noted the need for additional work on specific methods for using existing systematic reviews. Our intervening experience in implementing this guidance has also identified additional challenges, particularly in grading the strength of evidence and presenting the body of evidence when existing systematic reviews form part of the overall evidence base.

The lack of guidance has led to variable perspectives about and usage of existing systematic reviews across the EPC program. In particular, uncertainty and lack of guidance has led some EPC researchers to avoid integrating existing systematic reviews within the strength of evidence judgments and summaries. Omitting existing reviews from consideration when assessing the strength of the evidence is unsatisfying for the EPCs and for the audiences of our reports, as recently noted by the Eisenberg Center.3 Some EPCs have chosen to integrate existing systematic reviews into the strength of evidence ratings, but without guidance on how to implement such integration, the process has been inconsistent.

The objectives of this white paper are: (1) to identify areas where existing guidance may be adopted or adapted, and (2) to suggest approaches of focused areas for future work and additional guidance needs. Our findings are based on a summary of current guidance and discussions with directors and staff at the current EPCs.

Key methodological steps in deciding whether and how to use existing systematic reviews are illustrated in Figure 1 and in accompanying Table 1 (adapted from Whitlock, et al.1). In this paper, these steps were used to classify existing guidance from other systematic review organizations and to focus the discussion with EPCs. Table 1 provides definitions for the key steps in Figure 1.

Figure 1 Methodological steps in using existing systematic reviews

A figure titled “Figure 1. Methodological steps in using existing systematic reviews”. This figure depicts a flow diagram of the steps involved in using existing systematic reviews. The first box contains the text “Step 1. Locate existing SR(s)”. An arrow flows from this box to a diamond below containing the text “Existing SR(s)?”. An arrow with the text “Yes” flows from this diamond to a box below. This box contains the text “Step 2. Assess relevance” with three bullet points “Questions, Methods, Search dates”. An arrow flows from this box to a diamond below containing the text “Relevant SR(s)?” A line to the right of this diamond with the text “No” leads to open text “Stop. Proceed with SR of primary evidence. Use ‘almost’ relevant SRs to frame and provide context (Contextual Use). Scan References of ‘almost’ relevant SRs to check new search results.” An arrow below the diamond with the text “Yes” leads to a box containing text “Step 3. Assess quality of existing SR(s)”. An arrow below this box leads to a diamond containing the text “Sufficient Quality?”. A line to the right of this diamond with the text “No” leads to join an arrow from the text above flowing into a box below containing the text “Scan References, Check New Search Results”. An arrow below the diamond with the text “Yes” leads to a box containing the text “Step 4. Determine appropriate use and incorporate existing SR(s)” a line to the right of this box leads to four boxes containing the text “Scan References, Check New Search Results”, “Use Existing Search”, “Use Existing Data Abstraction, Study-level Risk of Bias Assessments and/or Synthesis”, “Use Complete Review”. An arrow below the box with the text “AND” leads to a box containing the text “Step 5. Report methods and results from using existing SR(s)”.

Table 1 Definitions of terms used in Figure 1

Locate Existing SR(s)
A defined and reproducible approach to efficiently identify existing systematic reviews for possible use in conducting a newly proposed systematic review, including updates.
Assess Relevance
Methods by which existing systematic reviews identified in Step 1 can be evaluated as to whether they are similar enough to the newly proposed review to obviate the need for conducting one or several steps in undertaking the newly proposed review. Relevance evaluation considers how well the existing reviews' research questions and inclusion/exclusion criteria for population, interventions, comparators, outcomes, settings, and study designs match those of the new systematic review, and how recently existing reviews' literature searches were concluded. Use ‘almost’ relevant SR(s) when selecting, developing, and/or refining questions and providing context for a newly proposed systematic review (i.e., Contextual Use) and scan references to check new search results.
Assess Quality of Existing SR(s)
Methods by which relevant existing systematic reviews can be evaluated for quality of methodological approach, using AMSTAR (A Measurement Tool To Assess Systematic Reviews) or other commonly used tools, with a focus on potentially incorporating only reviews meeting certain quality criteria into the proposed review.4, 5
Determine Appropriate Use And Incorporate Existing SR(s)
Methods by which to determine appropriate uses for relevant, high-quality existing systematic reviews in the proposed review. Incorporate existing SR(s) or use information from existing systematic reviews to supplement or supplant one or more activities that would be conducted from scratch for the newly proposed review. Use of existing systematic reviews may include: (1) using the existing systematic review(s)' listing of included studies as a quality check for the literature search and screening strategy conducted for the new review (Scan References); (2) using the existing systematic review(s) to completely or partially provide the body of included studies for one or more Key Questions in the new review (Use Existing Search); (3) using the data abstraction, risk of bias assessments, and/or analyses from existing systematic reviews for one or more Key Questions in the new review (Use Data Abstraction/Syntheses), or (4) using the existing systematic review(s), including conclusions, to fully or partially answer one or more Key Questions in the new review (Use Complete Review).
Report Methods and Results From Using Existing SR(s)
Standards for reporting the rationale for incorporating existing systematic reviews and the methods by which specific existing systematic reviews were located, assessed, and incorporated into the current systematic review. Standards for reporting results in the current systematic review that rely on evidence and/or analysis from existing systematic reviews and caveats or limitations associated with that approach; guidance about discussing how findings of the current systematic review compare and contrast with those of existing relevant systematic reviews.

Note: SR=systematic review.