# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jeanne-Marie Guise, M.D., M.P.H. for providing content edits; Suchitra Iyer, Ph.D. for content editing; Rose Relevo, M.L.I.S., M.S. for performing gray literature search; Timothy Wilt, M.D., M.P.H. for conducting interviews; and the Evidence-based Practice Center staff for participating in interviews to share their expertise and insight (see Appendix A for list).