# Discussion

There is consensus amongst systematic review organizations and the EPCs about some aspects of incorporating existing systematic reviews. Best practice requires a discussion of existing systematic reviews in the introduction and discussion sections of any new review. In all reviews, it is important to discuss how the current systematic review conclusions concur or differ from previous reviews. There remain, however, challenges for review authors attempting to incorporate existing systematic reviews. The methodological steps of using existing systematic reviews, status of existing guidance, and recommendations are provided in Table 3.

Table 3 Guidance recommendations for methodological areas in using existing systematic reviews

Methodological Area | Guidance Status | Recommendations/Further Work Needed
Locating existing reviews | Current EPC guidance is time intensive | Narrow search to locate only highly relevant, well-done, very recent existing reviews; consider narrowing further to specific sources like EPC or Cochrane. Empiric study of comprehensive versus limited consideration of specific sources may be warranted. Consider how much documentation of search strategies and yields is required for transparency.
Assessing relevance | EPC guidance exists | Follow current guidance.
Assessing review quality | Current tools, such as AMSTAR, have limitations and none consider primary literature included in the reviews | Empiric evidence of quality rating approaches is needed. Consider which currently available (or soon to be available) tools best fit the EPC program's needs.
Determining Use
Scanning references | EPC guidance exists | Follow current guidance.
Search strategy/results of existing searches | EPC guidance exists | Empiric evidence for considering searches from >1 review and considering excluded studies is needed.
Data abstraction | Current guidance is limited | Guidance needed for specific scenarios and for confirming accuracy of abstracted data.
Study-level risk of bias assessments | Guidance available for primary studies | Guidance is needed for when to accept or repeat assessments from existing reviews.
Synthesis | Current guidance is limited | Guidance needed for specific scenarios and for assessing strength of evidence when integrating existing review.
Methods and results reporting | EPC guidance exists | Guidance needed on level of detail necessary for all aspects, and options with worked examples needed for evidence tables.

Note: EPC=Evidence-based Practice Center.

Remaining areas of uncertainty may be addressed through a variety of methods. How best to construct evidence tables that combine primary studies and evidence from existing reviews may be addressed through discussions with end users of EPC reports. Methods research could assess the minimum quality control needed for using prior data abstractions or the impact on conclusions of a search of systematic reviews limited to specific sources. Finally, a symposium of systematic review organizations may be needed to develop consensus on reporting standards for communicating how prior reviews are incorporated. Future EPC program workgroups are taking up this challenge.