# Participating EPC Members

Brown University
- Issa Dahabreh, M.D., M.S.
  Associate Director

ECRI Institute
- Karen Schoelles, M.D., S.M., FACP
  Director
- Jonathan Treadwell, Ph.D.
  Associate Director
- Wendy Bruening, Ph.D.
  Senior Research Analyst,

Johns Hopkins University
- Renee Wilson, M.S.
  Project Manager
- Lisa Wilson, Sc.M.
  Project Manager

Kaiser
- Jennifer Lin, M.D., M.C.R.
  Associate Director

Minnesota
- Mary Butler, Ph.D., M.B.A.
  Associate Director
- Michelle Brasure, Ph.D.
  Project Director

Pacific Northwest
- Roger Chou, M.D., FACP
  Director

RAND
- Margaret Maglione, M.P.P., B.A.
  Associate Director

RTI-UNC
- Nancy Berkman, Ph.D.
  Methodologist

University of Alberta
- Lisa Hartling, B.Sc.P.T., M.Sc., Ph.D.
  Director
- Donna Dryden, Ph.D.
  Associate Director

Vanderbilt
- Nila Sathe, M.A., M.L.I.S.
  Program Manager