# Results

## Literature Review

From 1,591 candidate references, 166 were deemed relevant and reviewed in full text, and 46 articles were included. Eighteen of the studies contained original data, 11 were narrative reviews, 9 were commentaries or editorials, and 6 included their own frameworks for categorizing types of evidence needs or decisions made in the health system context.

### Types of Questions/Decisions for Which Health Systems Seek Evidence

Three articles provided a broad categorization of evidence needs of health systems. Makkar 2015^13^ provides a framework with four ways in which research is used in decisionmaking: (1) to prioritize issues or actions; (2) to provide new ideas, understanding, or concepts to clarify thinking without directly influencing decisions; (3) to persuade stakeholders or to justify decisions; and (4) to meet external requirements, such as regulatory or funding mandates to use research evidence (e.g., Magnet status for hospitals). Ølhom 2015^14^ describes a systematic review of studies on the information needs of hospital managers for a European initiative (AdHopHTA) to strengthen the use of HTA by hospitals. They identified 74 types of information needs and categorized them into ten domains: health problem and current use of technology, description and technical characteristics of technology, clinical effectiveness, safety aspects, costs and economic evaluation, and ethical, organizational, social, legal, political and strategic aspects. Following the completion of the systematic review, the same researchers conducted face-to-face interviews with 53 hospital managers in 9 European countries to understand the managers’ information needs regarding investments in new health care technologies.^15^ The most commonly cited needs were in the clinical effectiveness and economic domains, namely reimbursement and budget impact analysis, not societal level cost-effectiveness analysis. Interviewees also mentioned interest in the political and strategic domain, particularly regarding the hospitals’ strategic research priorities, prestige-building, competition with other hospitals, and investments.

Studies that reported on questions and decisions for which health systems seek evidence are summarized in Evidence Table C-1 in the Appendix. The studies show that health systems’ questions can be asked at various levels, including the level of a committee, a unit/practice, department, hospital, or a whole health system level. Thematic review of the available studies demonstrates that the various categorization approaches converge into three overlapping areas. In Box 1, we summarize the three categories of decisions and questions for which health systems seek evidence.

Box 1 Decisions and questions for which health systems seek evidence

- Technology (e.g., drugs, devices, products and supplies) adoption, purchasing and disinvestment
- Health services offerings (e.g., service lines, community programs; care processes; quality improvement and safety interventions; implementation strategies; research programs)
- Governance, financial, and delivery arrangements (payment incentive programs; accountable care; public reporting; care coordination; budgeting and infrastructure planning; implications of population health needs; workforce planning regarding roles, training, and credentialing)

#### 1 Adoption of Medical Technology

Much of the literature on decisionmaking and use of evidence in health systems focuses on the acquisition of health care technology (i.e., drugs, biologics, devices, equipment supplies, procedures, programs, support systems).^16^ Luce and Brown describe the results of a survey of 30 organizations including hospitals, health maintenance organizations (HMOs), public and private payers, and group purchasing organizations (GPOs). Participants from hospitals cited decisions on purchasing, controlling costs, marketing, and avoiding early obsolescence as reasons for their use of HTAs.^17^ Health maintenance organizations noted their obligation to cover interventions once they become “standard medical care” rather than “experimental” as impetus for decisions about examining new health care interventions.

Studies from the United States, United Kingdom and Australia showed that formulary decisions were one of the most common decisions for which health systems commonly required evidence.^18, 19^ In one study, the most common technologies reviewed by HTA programs were drugs (24%), devices (19%), and care processes (12%).^18^ Service managers in Australia considered safety and effectiveness the most important criteria when introducing or discontinuing new technologies. However, they acknowledged that budgetary considerations heavily influenced decisions about the uptake and diffusion of new technologies.^20^ Budget allocation and investment decisions were common reasons for seeking evidence in studies of hospital-based HTA included in a review by Gagnon.^21^

Several other studies described decisions for which organizations requested evidence syntheses, including choices between alternatives when standardizing products across a system, and choosing between vendors or manufacturers of similar products.^18–24^ A health system in Australia sought evidence to inform decisions about disinvesting in technologies and practices.^25^

#### 2 Health Services Offerings

Several studies described use of evidence in strategic decisionmaking and implementation. Examples included addressing inequalities and disparities through developing new community programs and service lines.^26^ A clinical service line is an organizational strategy for planning, marketing and delivering multidisciplinary health care services defined by a clinical intervention, health condition, or population group.^27^

Others described initiatives for improving quality and safety of care by putting new processes in place, using tools such as clinical pathways. Several other studies reported evidence requested for determining implementation strategies for clinical programs or policies.^18, 19, 22, 28, 29^

When researchers in British Columbia, Canada, gathered researchers and decisionmakers from various levels in the six provincial health authorities to consider priority setting for future research in health care,^30^ they learned that staff were concerned about deciding how to effectively make decisions and set priorities, suggesting a need for evidence about the process of decisionmaking in health systems.

#### 3 Governance, Finance and Delivery Models

Lavis 2010^11^ reviewed an inventory of HTAs produced by nine agencies during 2003–2006 and interviewed Canadian health care managers and policy makers. Decisions about governance, financial, and delivery arrangements require research evidence to inform problem definition, option framing and assessment, and implementation plans.

Several studies describe evidence needs in these categories. Cumpston and colleagues 2012 examined the work of the Cochrane Effective Practice and Organisation of Care (EPOC) group, which focuses on systematic reviews of professional, financial, organizational and regulatory interventions for improving practice and organization of health care services.^31^ After reviewing published EPOC review topics, the authors surveyed Australian health policymakers to identify gaps in the topics covered, and summarize their findings using the EPOC categories. Examples of the structural category include the need for evidence on interventions to improve population health and evidence to help the health system predict future demands for health services. Health systems the need to predict future demand to prepare for workforce recruitment, organization, and training, as well as to plan for infrastructure needs.^31^ Provider-oriented evidence needs include topics such as defining roles for allied health professionals and hospitalists, recruiting minorities to the workforce, and improving cultural competence. Patient-oriented needs include interventions to improve access and to serve special populations (e.g., rural, indigenous, refugees, prisoners) and interventions to promote community engagement in health service planning. Regulatory topics include the impact of credentialing of health professionals on safety and quality of care, and identifying interventions to improve coordination of services when there are multiple payers/funders involved.^31^ In addition, the authors of this and other studies identified the need for evidence to support financial decisions, including topics such as the impact of different funding models and financial incentives on demand for, quality of, and access to care.^31, 32^ Makkar 2015 identified the need for evidence to support the response to organizational or legislative mandates.^13^

A survey of the operational partners of the U.S. Veterans Health Administration’s Evidence-based Synthesis Program (VA ESP) showed that rapid reviews (median completion time 14.5 weeks) were commonly (72%) requested in response to regulatory and policy directives.^28^ For example, a report that evaluated the quality of care provided by advanced practice nurses was requested to inform consideration of practice authority expansion.^28^

### Types of Evidence Synthesis Sought by Health Systems

Several studies have examined types of products or formats of evidence syntheses intended for use by decisionmakers. In one previous EPC methodology project, rapid review products were categorized based on extent of synthesis. “Inventories” listed what evidence is available. “Rapid responses” presented best available evidence such as systematic reviews and health technology assessments with no formal synthesis. “Rapid reviews” synthesized the quality of and findings from the evidence, often including primary studies. “Automated approaches” generated meta-analyses in response to user-defined queries.^33^ In a second EPC methodology project, several end-users were interviewed (key informants including guideline developers, health care providers/health system organizations, research funders, and payers/health insurers).^10^ Informants described the use of evidence inventories “to stimulate discussion, challenge the status quo or get a sense of the literature when there is a pressing concern.” They reported that “rapid responses and rapid reviews may be more relevant for issues (often narrow questions) that arise within the clinical setting specific to a health system (where it may be more feasible to narrow the scope), or when interest is focused more on implementation (e.g., tailoring the evidence to a given region/setting).” One interviewee describing the tension between rigor and efficiency stated, “operationally-oriented folks are willing to take a risk on the absolute correctness of the answer in order to do something and to do it reliably across the delivery system.”

The VHA ESP surveyed health system leadership about their use of the program’s rapid reviews.^28^ There was a high level of agreement that the rapid reviews were influencing the delivery system. A similarly designed study in a large academic health care system suggested the same.^18^

Members of Pharmacy and Therapeutics committees (pharmacists and physicians from various health systems and organizations) participating in focus groups^34^ were asked about their use of AHRQ EPC Program Comparative Effectiveness Reviews (CERs). Only 26% reported using the reviews in their organizations. Participants described them as not being sufficiently timely, specific, or conclusive for their purposes. Pharmacy and Therapeutics committees usually review new products, whereas CER reviews are more useful for evaluating therapeutic classes of existing drugs. The wide focus and lack of specificity were a challenge to use when making specific decisions. They also commented on the need for more decisive information whereas most CER reports were perceived to be inconclusive.

Wye 2015^35^ studied the use of evidence by local policymaking bodies in the U.K. and pointed out that many academic research products are not relevant to their decisions, arguing that generalizable evidence lacks local context: “Local information often trumped national evidence, academic research or information from other localities.” Commissioners, “will always struggle to apply systematic reviews and randomized controlled trials, because paradoxically the very qualities that create such context-free, gold standard research render the studies less useful to commissioners.”^35^ Instead, “commissioners want “killer” stories that are rich in context.”^35^ In contrast, VHA executive level policymakers and their staff preferred RCTs, but also valued other types of evidence, such as case studies and patient preference studies.^36^

Others also mentioned the need for local contextual information or applicability information, and descriptions of the uncertainty of the findings.^11, 35^ Such contextual information is critical for decisionmaking and is consistent with the GRADE Evidence to Decision framework, which describes several discrete factors, other than effectiveness evidence, needed to make decisions (e.g., cost effectiveness and resource use, equity, acceptability, feasibility and values).^37^

In contrast, other health services researchers experienced in engaging policymakers and health care managers argue that systematic reviews can be useful to these groups, and compiled a list of “myths” about the suitability of systematic reviews for use by decisionmakers.^38^ They attempted to counter these myths by reviewing evidence included in the Canadian Health Systems Evidence Website (www.healthsystemsevidence.org), which covers topics including governance, financial arrangements, delivery arrangements, and implementing change in health systems. While acknowledging that more systematic reviews addressing policymakers’ questions are needed, they argued that systematic reviews can “level the playing field” when there are multiple stakeholders with different points of view. When all interested parties work from the same evidence, engagement is more likely. They also argued that “empty” systematic reviews (i.e., systematic reviews with no eligible studies to answer the question at hand) could be useful for decisionmaking. Finally, they note that exploring heterogeneity in systematic reviews can facilitate understanding about why interventions work in some settings and not others.

Additional descriptions are provided in Evidence Table C-2 in the Appendix. Together these studies identified several key characteristics of evidence synthesis products favored by health systems, as shown in Box 2.

Box 2 Characteristics of evidence synthesis products favored by health systems

- Short production times
- Timely topics
- Narrow focus; addressing specific questions related to technology acquisition or service line offerings
- Practical and implementable
- Provide guidance for action, even if evidence is less strong than ideal (e.g., case studies when controlled trials are not available)
- Provide contextual information (e.g., about cost, patient preferences and values, feasibility, acceptability) that supplement effectiveness evidence
- Incorporate local evidence and context

### Tools for Promoting Use of Evidence in Health System Decisions

Although this question was not included in the initial proposed framework, the literature review suggested that this issue is likely important for health systems and can optimize their use of evidence. Gagnon 2014 conducted a systematic review of instruments to assess organizational readiness for knowledge translation in health care, identifying 26 instruments.^39^ A number of studies described self-assessment tools for use by health systems decisionmakers to evaluate readiness and resources for utilizing evidence in decisions (e.g., Catallo 2014^40^, Lefebre 2010,^41^ Gifford 2014^42^, Gagnon 2014^39^)

Perrier 2011^43^ et al conducted a systematic review on interventions encouraging the use of systematic reviews by health policymakers and managers. In the single randomized trial identified, Dobbins 2009^44^ found that showing tailored messages combined with access to a registry of systematic reviews had a significant effect on policies made in a health department in Canada.

Ellen 2014^45,46^ 2013^47^ used surveys and qualitative studies to determine the barriers and facilitators for using evidence in health system decisionmaking. Establishing an environment that is conducive to use of evidence includes appropriate infrastructure, facilitating “push” efforts by knowledge brokers to disseminate research evidence to potential users, “pull” efforts by health system decisionmakers, “linkage and exchange” efforts facilitating relationships between researchers and knowledge users, and evaluation of knowledge translation efforts. Innis 2015^48^ also reported on such barriers and facilitators in a scoping review that emphasized the importance of organizational culture, leadership, linkage of evidence use to the organization’s strategic direction, presence of champions and appropriate infrastructure.

The focus group study with Pharmacy and Therapeutics committee members mentioned previously found the participants were interested in attending or completing a CER training program to help them use CER reviews in preparing evidence summaries for decisionmaking. In particular, they wanted training in evaluation of “evidence hierarchies,” and wanted online course delivery.^34^

In several studies, decisionmakers were interviewed or observed to identify preferences for presentation format. In general, they preferred summaries that were brief, presented in a “graded” format (key messages, executive summary) or presented verbally.^11, 18, 22, 35^

Two systematic reviews^49, 50^ addressed decisionmakers preferences for various derivative products based on systematic reviews. One found that decisionmakers described summary of findings tables with event rates and absolute differences as preferable.^49^ The other found that mailed bulletins with synopses of systematic reviews that were distributed to clinicians were associated with some practice improvement.^50^ Wye 2015 studied the use of evidence by local policymaking bodies in the U.K. and noted that policymakers preferred verbal over written presentation.^35^

As described previously, health system decisionmakers often expressed a desire for more “conclusive” and “decisive” evidence. Studies by Makkar 2015^13^, Aicken 2012^51^, Goetghebeur 2008^52^, Munn 2014^53^, and Munn 2014^53^ described approaches that may address this perceived need by providing tools such as multicriteria decision analysis (MCDA), conjoint analysis, decision analytic modelling, or other quantitative approaches to clarifying value judgments and incorporating evidence. These approaches would require partnership between evidence synthesis producers and health systems capable of manipulating and processing the evidence to make local decisions.

Box 3 Characteristics of tools for promoting use of evidence syntheses by health systems

- Preparation for using evidence: system self-assessment tools for use of evidence and knowledge translation
- Customized information delivery and access to information resources
- Health system infrastructure and local champions for use of evidence in decisionmaking
- Layered format that allows different users with different needs to access formats that range from a highly focused presentation to highly detailed information
- Preference for event rates, natural frequencies, and absolute differences, over relative measures
- Oral presentation of report findings to users
- Training and education for users

The studies relevant to this domain are found in Evidence Table C-3 in the Appendix.

## Original Data

Original data were available from four evidence synthesis programs that addressed the research evidence needs of individual health systems: Kaiser Permanente Southern California (KPSC), Veterans Health Administration (VHA) Evidence Synthesis Program (ESP), ECRI Institute’s Health Technology Assessment Information Service (HTAIS), and Penn Medicine Center for Evidence-based Practice (CEP). The experiences of these four centers are summarized in Table 1.

Table 1 Experience from four organizations: characteristics of evidence needs of hospitals and health care systems

Institution Description | Study Period N | Product Type | Requestor Type | Technology Class | Clinical Specialty | Other Comments
ECRI HTAIS Nonprofit health services research organization providing Web-based Health Technology Assessment Information Service (HTAIS) to hospital and third-party payer members on a subscription basis | CY2016 307 | 80% Rapid Response ^(1)^ 13% Product Comparison ^(1)^ 7% Special Reports ^(2)^ | 70% Purchasing, value analysis, or supply chain professionals 12% Clinical departments 10% Nursing 3% Health technology assessment groups 3% Medical staff 2% Strategic planning | 47% Devices 21% Procedures 16% Implants 3% Drugs 3% Biotechnology 3% Service 2% Assistive technology 2% Laboratory test 1% Diet/Nutrition 1% Health IT 1% Complementary/Alternative | 24% Surgery (general, bariatric, cardiothoracic, neurosurgery, plastic and transplant) 8% General medicine 7% Cardiology 6% Nursing 6% Orthopedic 4% Oncology 4% Gastroenterology 4% Clinical lab, diagnostic imaging 3% Critical care 3% Infectious disease 3% Dermatology | 307 of 495 HTAIS reports written in 2016 were for hospitals or health systems. Health systems had a median of 4.5 hospitals per system, range 1 to 34 hospitals; 61% of systems are moderately or highly centralized; 27% of hospitals have <100 beds; 20% are rural; 31% have no academic affiliation. Rapid responses are completed in 10–15 business days with no formal synthesis Product comparisons are overviews of rapid responses for multiple brands of a technology or product Special reports are qualitative reviews of multiple brands and multiple technologies or products for particular service lines.
VHA ESP Established in 2007 and funded by QUERI. Has 4 centers, each with a University affiliation and close ties to AHRQ Evidence-based Practice Centers. Governance provided by a Coordinating Center and a Steering Committee of VHA leadership. | FY2011–2016 98 | 17% Rapid Review ^(2)^ 8% Evidence Map ^(3)^ 60% Traditional Review ^(3)^ | 94% non-academic Subject-Matter Experts with VA operation decision-making authority, including National Program Offices, Central Office, and Chief Consultants | 31% Care processes 19% Policy 18% Non-drug, non-device intervention 14% Devices 12% Test, scales, risk factors 8% Drugs 3% Medical/surgical procedures 3% Support system (e.g., counseling) 3% Prevalence, epidemiology | 44% General medicine 10% Cardiology 8% Pain medicine 5% Surgery (general, cardiothoracic) 4% Ophthalmology 3% Gastroenterology 3% Nursing 3% Oncology 2% Nephrology 2% Neurology 2% Sleep medicine 1% Geriatrics 1% Infectious disease | 35% of all reports include meta-analysis 36% of all reports have led to journal publications 100% of reports are publicly available within 1 year
Penn CEP Evidence-based practice center established in 2006 to serve a large urban academic health care system | FY2006–2016 308 | 58% Rapid Review ^(2)^ 28% Advisory ^(2)^ | 33% Clinical departments 17% CMO 11% Purchasing 10% Nursing 8% Quality 8% Formulary 7% Administrative departments | 21% Drugs 21% Care processes 17% Devices 12% Policy 11% Tests 8% Procedures 5% Biologics 5% Support systems | 16% Nursing 11% General medicine 9% General surgery 8% Critical care 7% Orthopedics 7% Cardiology 6% Hematology 4% Infectious diseases 4% OBGYN 3% Oncology | 14% performed original meta-analyses 31% performed GRADE assessments 13% informed informatics tools
KPSC EBM Services Southern California-based group of 11 evidence specialists who conduct evidence reviews to support clinical practice guideline development, health technology assessment (KPSC and KP National) and evidence-based implementation initiatives for a large national HMO covering # states | FY 2016 347 | 60% Rapid Review ^(1)^ 20% Traditional Review ^(2)^ 20% prior assessments or informational (citations, resources, etc.) <1% Guideline support | 65% Clinical departments 35% Member Services (new tech evidence reviews for patient appeals cases) | 45% devices 40% procedures 15% tests 10% other | 30% Internal Medicine Subspecialties 10% Orthopedics 6% Neurology/Neurosurgery 6% Physical Med & Rehab 6% Psychiatry/Behavioral Health 5% Ophthalmology 5% Surgery 5% Urology 4% HNS/ENT 4% Pediatrics 4% Radiology 3% OB/GYN 2% Dermatology 1% Allergy, Family Med, Plastic Surgery <1% Other (Anesthesiology, Emergency Med, Hospital Med, Nuclear Med, Pathology) | One-third of review requests pertain to patient cases and have deadlines of 1–5 days due to regulatory requirements All other requests for evidence reviews have (generally) flexible due dates ranging from 4 to 12 weeks Support for 2 guidelines in FY2016, work includes updating existing systematic reviews and adapting/adopting external guidelines, support entails ~300–350 hours per guideline

Abbreviations: CMO, Chief Medical Officer; CY, calendar year; ECRI HTAIS, ECRI Institute Health Technology Assessment Information Service; FY, fiscal year; GRADE; Grading of Recommendations Assessment, Development and Evaluation; Penn CEP, Penn Medicine Center for Evidence-based Practice; QUERI, Quality Enhancement Research Initiative; VHA ESP, Veterans Health Administration Evidence-based Synthesis Program; KPSC EBM Services, Kaiser Permanente Southern California Evidence-Based Medicine (EBM) Services Unit

Note:

1 Takes less than 1 month;

2 takes less than 3 months;

3 takes 8 months or more. Rapid Responses and Rapid Reviews are defined in Hartling 2017.

The number of products created annually by each center varied widely, from over 300 products a year for organizations like ECRI and KPSC that performed rapid reviews and served a large number of hospitals, to approximately 30 a year for Penn CEP, which performs rapid reviews but serves fewer hospitals, to less than 20 a year for the VHA ESP, which commonly performs traditional reviews for the national VA program. Many requests received by ECRI Institute did not lead to the generation of new evidence reports (205/702, 29%), and the requestor was directed to existing systematic reviews, evidence reports or other resources. Rapid products were the most common product performed except at the VHA (93% of the ECRI HTAIS reports within 10 to 15 business days, 60% of KPSC reports within 1 to 5 days as required by regulation for addressing patient requests, 86% of Penn Medicine CEP reports within 3 months). A wide range of clinical and administrative decisionmakers requested evidence reviews, and the topics were similarly broad—ranging from evidence to guide clinical care; purchasing of medications and devices; procedural and non-procedural interventions; and processes of care. Topics addressed by each organization were dictated by the needs of their requestors or strengths of the organization. For example, almost 70% of the VHA ESP reports addressed care processes, policies or non-drug, non-device interventions, while approximately 90% of ECRI reports addressed devices, procedures, implants, tests or other technologies. Data suggest that those requesting reports and the types of topics examined have changed over time as well. For example, the proportion of reports performed by the Penn CEP that were relevant to nursing practice increased from 6% (2/35) in the center’s first two fiscal years (2007–2008) to 31% (18/59) in the center’s two most recent fiscal years (2015–2016). Similarly, a prior publication (Jayakumar 2016) describing the Penn CEP noted that the proportion of reports addressing policy, managerial, or organizational support systems increased from 7% (7/109) in the center’s first 4 years to 24% (33/140) in their second four years.

Experience from the four centers is summarized in Table 1.

## Stakeholder Feedback

Two health system representatives, Lucy Savitz, Ph.D., M.B.A. and Charles P. Friedman, Ph.D. provided feedback on our initial framework and draft report. Our stakeholders’ perspectives on how the EPC program can best interact with learning health systems can be summarized in the following themes:

### Trustworthiness

Drs. Savitz and Friedman introduced a new domain to the framework—trustworthiness of evidence. This trustworthiness was described in two ways:

- How trustworthy is the evidence? Health systems making decisions based on the evidence need to know the reviewers’ level of confidence in the estimates of effect provided in the evidence summaries. This description is analogous to the strength of evidence (SOE) levels used by the EPC program when conducting systematic reviews.
- How trustworthy is the evidence synthesis group and how credible is the review process? Stakeholders emphasized the importance of trust and partnership between the health system and the evidence synthesis team and voiced that such trust is critical to acceptance of evidence summaries by health systems.

They also mentioned that a system might not trust the assigned SOE if it contradicts data or observations derived from their local setting. They expressed the concern that excessive labeling of evidence as low or insufficient is, in general, not helpful to health systems because they need to make decisions and act in real time, and cannot wait for future studies. They also mentioned the need for evidence summaries that present more decisive and practical results.

### Evaluation and Feedback

These health systems’ representatives described the need for evaluation, reassessment and feedback about the use of evidence in health systems. Such evaluation serves as a tool for continuous quality improvement, can close the loop on evidence uptake, and demonstrate barriers for using summarized evidence in decisionmaking. They described a conceptual model in which knowledge is available in a machine executable form, and a learning cycle in which data transitions to knowledge, then knowledge transitions to practice, and finally practice provides additional data and process feedback.

### Preparing Evidence for Use by Learning Health Systems

Drs. Savitz and Friedman suggested a role for evidence synthesis producers to assist in packaging and continuously updating evidence for real-time use by clinicians and other decisionmakers in learning health systems, with the vision of incorporating evidence into health information technology systems of the future. Such a role aligns with the concept of learning health systems.

### Engaging Health System Networks

Our health systems stakeholders mentioned a possible need for evidence synthesis programs to engage with networks of health systems (e.g., High Value Healthcare Collaborative) and data analytics services (e.g., Flatiron Health, ASCO CancerLinQ™), which may help identify and address research evidence needs across health systems as they evolve and change.

### Layered Knowledge Presentation

Drs. Savitz and Friedman corroborated the importance of layered information that starts with key messages (which are important for certain types of users within health systems) followed by information that is more detailed (for other users who want to focus on implementation or have other particular needs).

### Internal and External Evidence

Our stakeholders clearly differentiated between external evidence (summarized from published literature) and internal evidence (derived from the system’s own electronic health records or other local datasets), and expressed the importance of both types of evidence.

### Evidence Synthesis Producer Engagement With Health Systems

Lastly, Drs. Savitz and Friedman requested that this workgroup provide, in addition to a framework, recommendations that facilitate engagement of evidence synthesis producers with health systems.