# References

1 McGinnis JM. Evidence-based Medicine - Engineering the Learning Healthcare System. Stud Health Technol Inform. 2010;153:145–57. PMID: 20543243.20543243
2 Guise J-M, Chang C, Viswanathan M, . Agency for Healthcare Research and Quality Evidence-based Practice Center methods for systematically reviewing complex multicomponent health care interventions. J Clin Epidemiol. 2014;67(11):1181–91. PMID: 25438663. https://doi.org/10.1016/j.jclinepi.2014.06.010.25438663
3 Guise J-M, Chang C, Butler ME, . AHRQ Series on complex intervention Systematic Reviews–Paper 1: An introduction to a series of papers that provide guidance and tools for reviews of complex interventions. J Clin Epidemiol. 2017; PMID: 28720511. https://doi.org/10.1016/j.jclinepi.2017.06.011.28720511
4 Kelly MP, Noyes J, Kane RL, . AHRQ series on complex intervention systematic reviews–Paper 2: Defining Complexity, Formulating Scope and Questions. J Clin Epidemiol. 2017; PMID: 28720514. https://doi.org/10.1016/j.jclinepi.2017.06.012.28720514
5 Butler M, Epstein RA, Totten A, . AHRQ series on complex intervention systematic reviews–Paper 3: Adapting frameworks to develop protocols. J Clin Epidemiol. 2017; PMID: 28720510. https://doi.org/10.1016/j.jclinepi.2017.06.013.28720510
6 Viswanathan M, McPheeters ML, Murad MH, . AHRQ series on complex intervention systematic reviews–Paper 4: Selecting Analytic Approaches. J Clin Epidemiol. 2017; PMID: 28720515. https://doi.org/10.1016/j.jclinepi.2017.06.014.28720515
7 Pigott T, Noyes J, Umscheid CA, . AHRQ series on complex intervention systematic reviews–Paper 5: Advanced Analytic Methods. J Clin Epidemiol. 2017; PMID: 28720512. https://doi.org/10.1016/j.jclinepi.2017.06.015.28720512
8 Guise J-M, Butler ME, Chang C, . AHRQ series on complex intervention systematic reviews–Paper 6: PRISMA-CI Extension Statement & Checklist. J Clin Epidemiol. 2017; PMID: 28720516. https://doi.org/10.1016/j.jclinepi.2017.06.016.28720516
9 Guise J-M, Butler M, Chang C, . AHRQ series on complex intervention systematic reviews–Paper 7: PRISMA-CI Elaboration & Explanation. J Clin Epidemiol. 2017; PMID: 28720513. https://doi.org/10.1016/j.jclinepi.2017.06.017.28720513
10 Hartling L, Guise J-M, Hempel S, . Fit for purpose: perspectives on rapid reviews from end-user interviews. Syst Rev. 2017;6(1):32. PMID: 28212677. https://doi.org/10.1186/s13643-017-0425-7.28212677
11 Lavis JN, Wilson MG, Grimshaw JM, . Supporting the use of health technology assessments in policy making about health systems. Int J Technol Assess Health Care. 2010;26(4):405–14. PMID: 26362086. https://doi.org/10.1016/j.healthpol.2015.08.011.20923592
12 Wallace BC, Small K, Brodley CE, . Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium. 2012:819–24. https://doi.org/10.1145/2110363.2110464.
13 Makkar SR, Williamson A, Turner T, . Using conjoint analysis to develop a system of scoring policymakers’ use of research in policy and program development. Health Res Policy Syst. 2015;13:35. PMID: 26238566. https://doi.org/10.1186/s12961-015-0022-y.26238566
14 Ølholm AM, Kidholm K, Birk-Olsen M, . Hospital Managers’ Need for Information on Health Technology Investments. Int J Technol Assess Health Care. 2015;31(6):414–25. PMID: 26875930. https://doi.org/10.1017/S0266462315000665.26875930
15 Kidholm K, Olholm AM, Birk-Olsen M, . Hospital managers’ need for information in decision-making--An interview study in nine European countries. Health Policy. 2015;119(11):1424–32. PMID: 26362086. https://doi.org/10.1016/j.healthpol.2015.08.011.26362086
16 Goodman C. HTA 101: Introduction to Health Technology Assessment. Bethesda, MD: National Library of Medicine (US). 2004.
17 Luce BR, Brown RE. The use of technology assessment by hospitals, health maintenance organizations, and third-party payers in the United States. Int J Technol Assess Health Care. 1995;11(1):79–92. PMID: 7706016.7706016
18 Jayakumar KL, Lavenberg JA, Mitchell MD, . Evidence synthesis activities of a hospital evidence-based practice center and impact on hospital decision making. J Hosp Med. 2016;11(3):185–92. PMID: 26505618. https://doi.org/10.1002/jhm.2498.26505618
19 Umscheid CA, Williams K, Brennan PJ. Hospital-based comparative effectiveness centers: translating research into practice to improve the quality, safety and value of patient care. J Gen Intern Med. 2010;25(12):1352–5. PMID: 20697961. https://doi.org/10.1007/s11606-010-1476-9.20697961
20 Gallego G, Fowler S, van Gool K. Decision makers’ perceptions of health technology decision making and priority setting at the institutional level. Aust Health Rev. 2008;32(3):520–7. PMID: 20387326.18666881
21 Gagnon M-P, Desmartis M, Poder T, . Effects and repercussions of local/hospital-based health technology assessment (HTA): a systematic review. Syst Rev. 2014;3(1):129. PMID: 25352182. https://doi.org/10.1186/2046-4053-3-129.25352182
22 Mitchell MD, Williams K, Kuntz G, . When the decision is what to decide: using evidence inventory reports to focus health technology assessments. Int J Technol Assess Health Care. 2011;27(2):127–32. PMID: 21450127. https://doi.org/10.1017/S0266462311000031.21450127
23 Gutowski C, Maa J, Hoo KS, . Health technology assessment at the University of California-San Francisco. J Healthc Manag. 2011;56(1):15–30. PMID: 21323025.21323025
24 Barbieri M, Hawkins N, Sculpher M. Who does the numbers? The role of third-party technology assessment to inform health systems’ decision-making about the funding of health technologies. Value Health. 2009;12(2):193–201. PMID: 18700865. https://doi.org/10.1111/j.1524-4733.2008.00441.x.18700865
25 Harris C, Green S, Ramsey W, . Sustainability in Health care by Allocating Resources Effectively (SHARE) 1: Introducing a series of papers reporting an investigation of disinvestment in a local healthcare setting. BMC Health Serv Res. 2017;17(1):323. PMID: 28472962. https://doi.org/10.1186/s12913-017-2210-7.28472962
26 Crites GE, McNamara MC, Akl EA, . Evidence in the learning organization. Health Res Policy Syst. 2009;7:4. https://doi.org/10.1186/1478-4505-7-4.19323819
27 Byrne MM, Charns MP, Parker VA, . The effects of organization on medical utilization: an analysis of service line organization. Med Care. 2004:28–37. PMID: 14713737. https://doi.org/10.1097/01.mlr.0000102493.28759.71.14713737
28 Peterson K, Floyd N, Ferguson L, . User survey finds rapid evidence reviews increased uptake of evidence by Veterans Health Administration leadership to inform fast-paced health-system decision-making. Syst Rev. 2016;5(1):132. PMID: 27491354. https://doi.org/10.1186/s13643-016-0306-5.27491354
29 Xie F, Bowen JM, Sutherland SC, . Using health technology assessment to support evidence-based decision-making in Canada: an academic perspective. Expert Rev Pharmacoecon Outcomes Res. 2011;11(5):513–21. PMID: 21958096. https://doi.org/10.1586/erp.11.60.21958096
30 Smith N, Mitton C, Peacock S, . Identifying research priorities for health care priority setting: a collaborative effort between managers and researchers. BMC Health Serv Res. 2009;9:165. PMID: 19754969. https://doi.org/10.1186/1472-6963-9-165.19754969
31 Cumpston MS, Tavender EJ, Buchan HA, . Australian health policy makers’ priorities for research synthesis: a survey. Aust Health Rev. 2012;36(4):401–11. PMID: 22951094. https://doi.org/10.1071/AH11064.22951094
32 Gurtner S. Making the right decisions about new technologies: a perspective on criteria and preferences in hospitals. Health care Manage Rev. 2014;39(3):245–54. PMID: 23727787. https://doi.org/10.1097/HMR.0b013e3182993b91.23727787
33 Hartling L, Guise J-M, Kato E, . A taxonomy of rapid reviews links report types and methods to specific decision-making contexts. J Clin Epidemiol. 2015;68(12):1451–62.e3. PMID: 26278023. https://doi.org/10.1016/j.jclinepi.2015.05.036.26278023
34 Villa L, Warholak TL, Hines LE, . Health care decision makers’ use of comparative effectiveness research: report from a series of focus groups. J Manag Care Pharm. 2013;19(9):745–54. PMID: 24156643. https://doi.org/10.18553/jmcp.2013.19.9.745.24156643
35 Wye L, Brangan E, Cameron A, . Evidence based policy making and the ‘art’ of commissioning - how English healthcare commissioners access and use information and academic research in ‘real life’ decision-making: an empirical qualitative study. BMC Health Serv Res. 2015;15:430. PMID: 26416368. https://doi.org/10.1186/s12913-015-1091-x.26416368
36 Parker LE, Ritchie MJ, Kirchner JE, . Balancing health care evidence and art to meet clinical needs: policymakers’ perspectives. J Eval Clin Pract. 2009;15(6):970–5. PMID: 20367694. https://doi.org/10.1111/j.1365-2753.2009.01209.x.20367694
37 Alonso-Coello P, Schünemann HJ, Moberg J, . GRADE Evidence to Decision (EtD) frameworks: a systematic and transparent approach to making well informed healthcare choices. 1: Introduction. BMJ. 2016;353:i2016. PMID: 27353417. https://doi.org/10.1136/bmj.i2016.27353417
38 Moat KA, Lavis JN, Wilson MG, . Twelve myths about systematic reviews for health system policymaking rebutted. J Health Serv Res Policy. 2013;18(1):44–50. PMID: 23393042. https://doi.org/10.1258/jhsrp.2012.011175.23393042
39 Gagnon M-P, Attieh R, Ghandour EK, . A systematic review of instruments to assess organizational readiness for knowledge translation in health care. PLoS One. 2014;9(12):e114338. PMID: 25474622. https://doi.org/10.1371/journal.pone.0114338.25474622
40 Catallo C, Sidani S. The Self-assessment for Organizational Capacity Instrument for evidence-informed health policy: preliminary reliability and validity of an instrument. Worldviews Evid Based Nurs. 2014;11(1):35–45. PMID: 24127906. https://doi.org/10.1111/wvn.12018.24127906
41 Lefebre N. Knowledge to action: integrating the use of evidence in management decision making. Healthc Manage Forum. 2010;23(2):48–57. PMID: 21739839. https://doi.org/10.1016/j.hcmf.2010.04.005.21739839
42 Gifford W, Lefebre N, Davies B. An organizational intervention to influence evidence-informed decision making in home health nursing. J Nurs Adm. 2014;44(7/8):395–402. PMID: 25072229. https://doi.org/10.1097/NNA.0000000000000089.25072229
43 Perrier L, Mrklas K, Lavis JN, . Interventions encouraging the use of systematic reviews by health policymakers and managers: a systematic review. Implement Sci. 2011;6(1):43. PMID: 21524292. https://doi.org/10.1186/1748-5908-6-43.21524292
44 Dobbins M, Hanna SE, Ciliska D, . A randomized controlled trial evaluating the impact of knowledge translation and exchange strategies. Implement Sci. 2009;4(1):61. PMID: 19775439. https://doi.org/10.1186/1748-5908-4-61.19775439
45 Ellen ME, Lavis JN, Sharon A, . Health systems and policy research evidence in health policy making in Israel: what are researchers’ practices in transferring knowledge to policy makers? Health Res Policy Syst. 2014;12:67. PMID: 25491890. https://doi.org/10.1186/1478-4505-12-67.25491890
46 Ellen ME, Leon G, Bouchard G, . Barriers, facilitators and views about next steps to implementing supports for evidence-informed decision-making in health systems: a qualitative study. Implement Sci. 2014;9:179. PMID: 25476735. https://doi.org/10.1186/s13012-014-0179-8.25476735
47 Ellen ME, Leon G, Bouchard G, . What supports do health system organizations have in place to facilitate evidence-informed decision-making? A qualitative study. Implement Sci. 2013;8:84. PMID: 23915278. https://doi.org/10.1186/1748-5908-8-84.23915278
48 Innis J, Dryden-Palmer K, Perreira T, . How do health care organizations take on best practices? A scoping literature review. Int J Evid Based Healthc. 2015;13(4):254–72. PMID: 26134546. https://doi.org/10.1097/XEB.0000000000000049.26134546
49 Petkovic J, Welch V, Jacob MH, . The effectiveness of evidence summaries on health policymakers and health system managers use of evidence from systematic reviews: a systematic review. Implement Sci. 2016;11(1):162. PMID: 27938409 https://doi.org/10.1186/s13012-016-0530-3.27938409
50 Murthy L, Shepperd S, Clarke MJ, . Interventions to improve the use of systematic reviews in decision-making by health system managers, policy makers and clinicians. Cochrane Database Syst Rev. 2012; PMID: 22972142. https://doi.org/10.1002/14651858.CD009401.pub2.22972142
51 Aicken CRH, Armstrong NT, Cassell JA, . Barriers and opportunities for evidence-based health service planning: the example of developing a Decision Analytic Model to plan services for sexually transmitted infections in the UK. BMC Health Serv Res. 2012;12:202. PMID: 22805183. https://doi.org/10.1186/1472-6963-12-202.22805183
52 Goetghebeur MM, Wagner M, Khoury H, . Evidence and Value: Impact on DEcisionMaking--the EVIDEM framework and potential applications. BMC Health Serv Res. 2008;8:270. PMID: 19102752 https://doi.org/10.1186/1472-6963-8-270.19102752
53 Munn SR. Hospital-based health technology assessment: insights from New Zealand. PharmacoEconomics. 2014;32(9):815–7. PMID: 25117205 https://doi.org/10.1007/s40273-014-0202-6.25117205
54 Chambers DA, Feero WG, Khoury MJ. Convergence of Implementation Science, Precision Medicine, and the Learning Health Care System: A New Model for Biomedical Research. JAMA. 2016;315(18):1941–2. PMID: 27163980. https://doi.org/10.1001/jama.2016.3867.27163980
55 Insitute of Medicine. Engineering a learning healthcare system: A look at the future: Workshop summary: Washington, DC: National Academies Press; 2011.
56 Mitchell MD, Williams K, Brennan PJ, . Integrating local data into hospital-based healthcare technology assessment: two case studies. Int J Technol Assess Health Care. 2010;26(3):294–300. PMID: 20584358. https://doi.org/10.1017/S0266462310000334.20584358
57 Fleming C. Berwick brings the ‘Triple Aim’to CMS. Health Affairs Blog. http://healthaffairs.org/blog/2010/09/14/berwickbrings-the-triple-aim-to-cms/ 2015;15. Accessed April, 2017.
58 Insitute of Medicine. Integrating Research and Practice: Health System Leaders Working Toward High-Value Care: Workshop Summary. Washington, DC: National Academies Press; 2015.PMID: 2583487025834870.
59 Norris SL, Atkins D, Bruening W, . Observational studies in systemic reviews of comparative effectiveness: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1178–86. PMID: 21636246. https://doi.org/10.1016/j.jclinepi.2010.04.027.21636246
60 Murad MH, Almasri J, Alsawas M, . Grading the quality of evidence in complex interventions: a guide for evidence-based practitioners. Evid based Med. 2017;22(1):20–2. PMID: 27932400. https://doi.org/10.1136/ebmed-2016-110577.27932400
61 Murad MH, Mustafa RA, Schünemann HJ, . Rating the certainty in evidence in the absence of a single estimate of effect. Evid Based Med. 2017:ebmed-2017-110668. PMID: 28320705. https://doi.org/10.1136/ebmed-2017-110668.28320705
62 Carter BJ. Evidence-based decision-making: practical issues in the appraisal of evidence to inform policy and practice. Aust Health Rev. 2010;34(4):435–40. PMID: 21108904. https://doi.org/10.1071/AH09778.21108904
63 Lewis S. Toward a general theory of indifference to research-based evidence. J Health Serv Res Policy. 2007;12(3):166–72. PMID: 17716420. https://doi.org/10.1258/135581907781543094.17716420
64 Harris C, Allen K, Waller C, . Sustainability in Health care by Allocating Resources Effectively (SHARE) 5: developing a model for evidence-driven resource allocation in a local healthcare setting. BMC Health Serv Res. 2017;17(1):342. PMID: 28486973. https://doi.org/10.1186/s12913-017-2208-1.28486973
65 Harris C, Allen K, Waller C, . Sustainability in Health care by Allocating Resources Effectively (SHARE) 7: Supporting staff in evidence-based decision-making, implementation and evaluation in a local healthcare setting. BMC Health Serv Res. 2017;17(1):430. PMID: 28637473. https://doi.org/10.1186/s12913-017-2388-8.28637473
66 Insitute of Medicine. Best care at lower cost: the path to continuously learning health care in America: Washington, DC: National Academies Press; 2013.
67 Bindman AB. The Agency for Healthcare Research and Quality and the Development of a Learning Health Care System. JAMA Intern Med. 2017; PMID: 28542694. https://doi.org/10.1001/jamainternmed.2017.2589.28542694
68 Bambra C, Joyce KE, Bellis MA, . Reducing health inequalities in priority public health conditions: using rapid review to develop proposals for evidence-based policy. J of Public Health (Oxf). 2010;32(4):496–505. PMID: 20435581. https://doi.org/10.1093/pubmed/fdq028.20435581
69 Jackson GL, Zullig LL, Zafar SY, . Using NCCN clinical practice guidelines in oncology to measure the quality of colorectal cancer care in the veterans health administration. J Natl Compr Canc Netw. 2013;11(4):431–41. PMID: 23584346.23584346
70 Moat KA, Lavis JN. 10 best resources for ... evidence-informed health policy making. Health Policy and Plan. 2013;28(2):215–8. PMID: 22717501. https://doi.org/10.1093/heapol/czs050.22717501
71 Wilson MG, Moat KA, Lavis JN. The global stock of research evidence relevant to health systems policymaking. Health Res Policy Syst. 2013;11:32. PMID: 24007378. https://doi.org/10.1186/1478-4505-11-32.24007378
72 Wilson MG, Lavis JN, Gauvin F-P. Developing a rapid-response program for health system decision-makers in Canada: findings from an issue brief and stakeholder dialogue. Syst Rev. 2015;4:25. PMID: 25875495. https://doi.org/10.1186/s13643-015-0009-3.25875495
73 Lavis JN, Permanand G, Oxman AD, . SUPPORT Tools for evidence-informed health Policymaking (STP) 13: Preparing and using policy breifs to support evidence-informed policymaking. Health Res Policy Syst. 2009(7(Suppl1):S13); PMID: 20018103. https://doi.org/10.1186/1478-4505-7-S1-S13.20018103
74 Anonymous. Becoming a meaningful user of health IT. Hosp Health Netw. 2010;84(12):48–58. PMID: 21268505.21268505
75 Boyko JA. Evidence-informed health policy making in Canada: past, present, and future. J Evid based Med. 2015;8(4):215–21. PMID: 26275217. https://doi.org/10.1111/jebm.12169.26275217
76 Goeree R, Levin L, Chandra K, . Health technology assessment and primary data collection for reducing uncertainty in decision making. J Am Coll Radiol. 2009;6(5):332–42. PMID: 19394574. https://doi.org/10.1016/j.jacr.2009.01.012.19394574
77 Lavis JN, Wilson MG, Moat KA, . Developing and refining the methods for a ‘one-stop shop’for research evidence about health systems. Health Res Policy Syst. 2015;13(1):10. PMID: 25971248. https://doi.org/10.1186/1478-4505-13-10.25971248
78 Ritrovato M, Faggiano FC, Tedesco G, . Decision-Oriented Health Technology Assessment: One Step Forward in Supporting the Decision-Making Process in Hospitals. Value Health. 2015;18(4):505–11. PMID: 26091605. https://doi.org/10.1016/j.jval.2015.02.002.26091605
79 Williams B, Perillo S, Brown T. What are the factors of organisational culture in health care settings that act as barriers to the implementation of evidence-based practice? A scoping review. Nurse Educ Today. 2015;35(2):e34–e41. PMID: 25482849. https://doi.org/10.1016/j.nedt.2014.11.012.25482849