# Recommendations for the AHRQ EPC Program

The IOM challenged research funding agencies to promote research into barriers to use of evidence at the point of care and to support research methods for improving the usefulness and accessibility of local (patient outcome data) and external (published research) evidence for patients and clinicians.^66^

Our work group discussed possible roles for the AHRQ EPC Program in meeting the evidence needs of learning health systems in the United States. Methods work already performed by the Agency that is relevant to decisionmaking by health systems includes work on methods for synthesis of evidence on complex interventions, such as interventions used by health systems to support quality improvement and healthcare delivery. Other methods research performed by the AHRQ EPC program relevant to health systems are those projects related to the production of rapid evidence synthesis products, including projects on rapid reviews and horizon scanning.

The former AHRQ Director, Dr. Andrew Bindman, commented that most health care organizations need help to develop processes to adopt and generate evidence. He stated that AHRQ “is the federal agency best positioned to serve as a facilitator that can help health care organizations make this transition [to learning health care systems],” based on the Agency’s experience developing methods for evaluating quality of evidence. He proposed that health systems could use these methods to judge the quality of both internal and external published evidence. He suggested that AHRQ could engage with health systems in “collaborative problem solving” as a means of learning how to support them.^67^

We considered roles that may be both desirable and feasible for AHRQ, given budgetary constraints and the complexity of current contracting mechanisms, and offer the following suggestions:

1. Create a standing advisory committee of health system leaders who can advise AHRQ on health system needs. Sponsor ongoing discussion forums with health systems for knowledge exchange (what evidence synthesis can provide; what health systems need) to
  a. Establish relationship/rapport
  b. Understand the timing and process of decision making
  c. Better understand distinct needs of different types of health systems and what they have in common in order to better consider how AHRQ/EPC work may best fit
  d. Enhance awareness of what AHRQ/EPCs have done, may be able to help with
  e. Identify specific topics of interest for which there are non-urgent decisional needs (i.e., situations that match a feasible timeline for the EPC program to produce a review). This might include particularly challenging topics of interest to multiple health systems (e.g., High Value Healthcare Collaborative; Vizient™ University Health System Consortium)
  f. Identify specific topics that fit technical brief, topic brief, or horizon scan paradigms and time lines
  g. Identify topics related to implementation, disinvestment, operational, delivery and policy needs
2. Sponsor methods work related to integrating local health system evidence (i.e., clinical and operational data) with external published research evidence, including through pilot projects between health systems and EPCs.
3. Sponsor methods work to assess or develop tools to assist health systems in applying evidence to decisions:
  a. Explore ways to digitally enable data from evidence synthesis to facilitate the easy reuse, update, or extraction of findings into health information technology systems or other derivative products.
  b. Develop brief audio versions or PowerPoint slides depicting key messages for topics of interest to health systems. Layer information using the “bite, snack, meal” concept. Provide training for EPCs on plain language concepts and examples. Explore ways to “push” information to more health systems through social media, e-mail, etc.
  c. Strengthen the accessibility, usability and functionality of the EPC Program Web sites (https://www.ahrq.gov/research/findings/evidence-based-reports/search.html and https://effectivehealthcare.ahrq.gov/) so that reports can be easily identified, retrieved and used by health systems. Create a set of criteria which can be used to define those reports of most interest to health systems (e.g., compare alternative approaches to delivery, address healthcare quality or safety measures, clinical informatics), and create a flag or icon next to those reports.
  d. For those reports meeting criteria of particular interest to health systems, a health system implementation toolkit could be published alongside the original report.
4. Involve interested health system partners and decisionmakers in the scoping for reviews they have nominated to identify their highest priority needs, with a goal of producing reviews that are focused, timely and relevant.
5. Leverage previous program experience with horizon scanning, topic briefs developed for program planning, and methods work on rapid reviews to develop new evidence synthesis products tailored to health systems. Engagement of health systems in the development process may promote trustworthiness in the EPC program, evidence synthesis process, and resulting product.
6. Shorten the time required to produce evidence reviews while maintaining a systematic rigorous approach. This could include
  a. More flexible contractual mechanisms such as non-competitive assignments for evidence products or allowing for bundling of topics so contracting only has to be done once (e.g., one EPC will do 3 brief products in a 6–12 week time frame over the next 6 months)
  b. Reduction of the various layers of public, peer and intra-agency review of reports
  c. Reorganization of the production process.
7. Consider when certain types of contextual information, including information on intervention components, intervention implementation, and feasibility, should be included in EPC Program reviews to improve usefulness for health system decisionmaking.
8. Explore mechanisms for identifying emerging health system types not yet represented in the literature and understanding their evidence needs.
9. Facilitate discussion with groups making large-scale efforts to improve health system decisionmaking through incorporation of evidence. Understanding how these systems develop a learning cycle with measurement of impact can inform AHRQ’s efforts in this area.
10. Partner with organizations closely aligned with health systems such as the Advisory Board, American Nurses’ Credentialing Center Magnet Program, the American Hospital Association, ECRI Institute, Hayes Inc., and Vizient Inc. to disseminate report findings.