# Methods

This project was commissioned by AHRQ as a methods project. The need for this project became apparent from years of EPCs’ experience working with health systems, discussions with EPC Directors, EPC Methods Steering Committee meetings, and discussions with AHRQ leadership. This work is one of several complementary AHRQ projects about Learning Health Systems, including AHRQ’s Comparative Health System Performance Initiative, which was designed to study how health care delivery systems promote evidence-based practices in care delivery.

## Aim

The aim of this project was to develop a framework to identify and categorize the types of decisions for which health systems might seek external evidence, including evidence regarding health care delivery and organization, using the following questions:

a. What is the nature of the decision?
b. What is the level of evidence required by health systems?
  i. What types of evidence would be needed for each type of decision?
  ii. What type of review, format and time frame would be needed?
c. Who is involved in the decision?
d. Are there types of decisions where EPC reports could substantially improve the decisionmaking process and quality of care in health systems?

## Data Sources

The data used in this study come from three sources: (a) literature search, (b) original data on evidence synthesis requests made to four evidence synthesis programs serving health systems, and (c) input from two health system stakeholders and EPC investigators, obtained during a face-to-face meeting at AHRQ in June 2017. A second workgroup’s report addresses this topic through interviews with health system stakeholders.

### Literature Search

Eligible publications summarize original data or present reviews, commentaries and opinion pieces that describe the research evidence needs of health systems. We defined a health system as at least one hospital and one group of physicians; or two or more health care provider organizations with common ownership, contractual integration (e.g., accountable care organizations) or formal referral arrangements. Eligible publications addressed who in a health system requested research evidence, what type of research evidence was requested, or why it was requested. We excluded non-English publications and those focusing on single health systems using their own local administrative or clinical data exclusively, rather than external research evidence, to inform decisions. We included studies from non-U.S. systems where the decisions were deemed to be similar to those faced by U.S. systems (e.g., U.K., Australia, Canada), but excluded those where the decisions are significantly different from those faced by U.S. systems.

We searched Ovid MEDLINE(R) Daily, Ovid MEDLINE(R) 1946-Present, and Ovid Medline Epub Ahead of Print, In-Process & Other Non-Indexed Citations to identify relevant citations. Results were limited by publication date (2007–2017) and to English-language. The search identified 1553 candidate citations. Full search strategy details are available in Appendix A.

We identified additional references by reviewing bibliographies of relevant studies and contacting experts. References were uploaded into Abstrackr^12^ and dually reviewed for relevance using predetermined criteria. We extracted data on the characteristics of health systems, the individuals asking questions, payment or policy incentives informing questions and approaches, and types of research evidence used to address questions.

### Original Data

A convenience sample of evidence synthesis review groups serving U.S. health systems was asked to provide a summary of the reviews performed for health systems over the last several years. These groups serve: Kaiser Permanente Southern California, a large integrated health system and not-for-profit health plan serving over 4.5 million members in Southern California; the Veteran’s Health Administration (VHA), the largest integrated health care system in the United States; ECRI Institute, a not-for-profit health services research organization that conducts reviews for health systems, payers and provider groups under commission or subscription; and Penn Medicine, a large academic health system in Philadelphia, Pennsylvania. Information requested included the number and types of requests received for evidence syntheses, as well as the specialty and topic area of the requests.

### Stakeholder Feedback

Two health system representatives (Lucy Savitz, Ph.D., from Intermountain Health Care and Kaiser Permanente Northwest, and Charles P. Friedman, Ph.D., Chair of the Department of Learning Health Sciences at the University of Michigan) were invited to review the approach and results of this work group and provide feedback. Additional stakeholder feedback was obtained from a second EPC workgroup that had conducted interviews with representatives of other health systems.

## Synthesis

Data were synthesized narratively and thematically. We started by developing an initial framework to guide discussion and analysis (See Appendix B). We used weekly phone conferences, electronic communications and a face-to-face meeting of the workgroup to reach consensus on the initial framework and to modify it based on the three data sources. A summary of the research question and approach is depicted in Figure 1.

Figure 1 Research question and methodology

This figure shows the aim of this report and its three data sources. The aim is to develop a framework for understanding evidence needs of health systems. Data sources are literature, original data and stakeholders’ feedback. The figure also describes the approach of this report which is meta-narrative & thematic synthesis and the output which consists of the domains essential for evidence synthesis to support health systems.