# Introduction

The field of systematic reviews has principally developed in response to the needs of clinicians, guideline groups, professional societies, and policy-makers, who required evidence summaries to answer clinical questions and underpin guidelines or policies. However, health care in the U.S. is increasingly delivered by large health systems involving one or more hospitals and clinical practice sites. This trend offers an opportunity to develop evidence synthesis products (e.g., systematic reviews, rapid reviews) to support these systems in their efforts to provide high quality evidence-based care, improve quality, and conduct practice-based research. Furthermore, the movement toward value-based purchasing and increased requirements for quality reporting is likely to increase the utility of evidence synthesis on a broad range of topics that extend beyond questions of clinical efficacy to questions about alternative strategies for improving health care delivery, product and practice standardization, patient safety and quality of care.

The Agency for Healthcare Research and Quality (AHRQ) has made working with health systems a priority, with a focus on helping systems transition to learning health systems. A learning health system was defined by the Institute of Medicine (IOM, now the National Academy of Medicine) Roundtable on Evidence-based Medicine as a system “designed to generate and apply the best evidence for the collaborative health care choices of each patient and provider; to drive the process of discovery as a natural outgrowth of patient care; and to ensure innovation, quality and value in health care.”^1^

Well-established evidence synthesis programs such as the AHRQ Evidence-based Practice Center (EPC) Program have produced evidence reviews for more than two decades. These reviews have come to be recognized as a standard for rigor and quality across many disciplines, covering a wide range of topics that can be relied upon when making important decisions. This expertise may be particularly important when addressing high value care and health care delivery, which are likely to be complex in nature. Moreover, the EPC Program has developed considerable expertise in performing systematic reviews of complex multicomponent interventions.^2–9^ However, the program has not previously examined the scope of topics for which health systems seek evidence or how health systems access and use evidence—for what types of decisions and at what point in the decisionmaking process.

Of 250 reports produced by the EPC Program since 2011, 40 (16%) address care delivery and population health topics that may be of interest to health systems (e.g., patient-centered medical homes, medication adherence, quality improvement strategies), and 159 (64%) address clinical conditions that many health systems encounter. The remainder of topics covered methodologic issues of greatest interest to systematic reviewers. Previous work with health system representatives has revealed a need for evidence synthesis products that address specific decisions that health system leaders make and can be prepared quickly (e.g. evidence inventories, rapid reviews, automated approaches).^10^ Similarly, a study of health technology assessments (HTAs) produced by nine agencies during 2003–2006^11^ suggested that decisions about governance, financial, and delivery arrangements require research evidence that informs problem definition, option framing and assessment, and implementation plans. These studies support the notion that health systems have unique evidence needs and that formats developed for clinical guideline developers may not meet the needs of health systems.

Evidence synthesis producers need to strengthen their partnerships with health systems to better understand their evidence synthesis needs. Strengthening such partnerships requires a conceptual framework that clarifies and categorizes their evidence needs. Such a framework could help the program and EPC researchers focus on the most appropriate evidence synthesis products for specific health systems.

The goal of this report is to present a conceptual framework to facilitate understanding of the potential areas for interaction between the EPC program and health systems. The framework categorizes the evidence needs of health systems, focusing largely on system use of external (i.e., published research) evidence. In addition, we explore the evidentiary needs and preferences for information presentation from health systems leaders participating in this project.