# Acknowledgments

The authors gratefully acknowledge the input of the late Robert Lewis Kane, M.D., who was a member of our workgroup until his unexpected death on March 6, 2017. Dr. Kane stimulated the conversation of our workgroup with his ideas and challenges, and inspired creation of the initial framework for our efforts (See Appendix B).

The authors also acknowledge two health system representatives, Lucy Savitz, Ph.D., and Charles P. Friedman, Ph.D. for their feedback on our initial framework and draft report.

Dr. Savitz is currently the vice president of Health Research at Kaiser Permanente Northwest and the Director of the Center for Health Research for Kaiser Permanente Northwest and Hawaii. She previously served as assistant vice president for delivery system science in the Intermountain Healthcare Institute for Healthcare Delivery Research. She was also an elected member of the Board of Directors for the High Value Health Care Collaborative, which includes 14 large health care delivery systems across the United States.

Dr. Friedman is the Josiah Macy Jr. Professor of Medical Education and Chair of the Department of Learning Health Sciences at the University of Michigan Medical School. He has extensive expertise in medical informatics and leads research on knowledge dissemination within the learning health systems, including at the national level. Previously, Dr. Friedman was the Deputy National Coordinator and Chief Scientific Officer at the Office of the National Coordinator for Health IT (ONC).

The authors additionally would like to gratefully acknowledge the contributions of Marguerite Koster, M.A., M.F.T. from the Southern California Kaiser Permanente Medical Group for providing the original data representing the Kaiser Permanente Southern California Evidence-Based Medicine (EBM) Services Unit.