# Discussion

In this report, we sought to develop a framework to facilitate understanding of the areas of potential interaction between evidence synthesis producers and health systems. After using several data sources including published literature, original data from evidence synthesis programs, and obtaining feedback from health systems stakeholders, we identified several domains that may help facilitate interaction between health systems and evidence synthesis producers and may aid in providing evidence summaries catered to the needs of health systems.

Successful engagement will require specifying the following:

- type of decision or question(s) of the health system,
- type of evidence synthesis or evidence synthesis product that will best address the question,
  ○ evidence synthesis users within the health system
  ○ optimal timing for evidence synthesis delivery during the decisionmaking process
- tools required to promote the use of evidence (which could be developed by the evidence synthesis program or by the health system), and finally a
- feedback or auditing mechanism to determine the success and impact of evidence integration into health system decisions.

Trustworthiness of the process of the evidence synthesis and communication of the trustworthiness of the evidence is an additional key domain.

These domains can serve as a taxonomy and facilitate engagement with the health system (Figure 2).

Figure 2 Domains or parameters to be specified for engagement of evidence synthesis programs with health systems

This figure shows 5 boxes that contain the 5 domains to be specified for engagement of evidence synthesis programs with health systems. These domains are: type of health system decision, type of required evidence synthesis, tools for promoting use of evidence, evaluation and feedback, and trustworthiness of evidence synthesis.

## Key Points

- Our review suggests that health system leaders’ decisions for which evidence is needed commonly include the acquisition of medical technology, including interventional devices and pharmaceutical interventions; the implementation or expansion of service line offerings; disinvestment and deimplementation of technologies: improvements in care processes; and the selection of governance, finance and service delivery models.
- Health systems often are interested in evidence for newer and emerging interventions.
- Health systems often require evidence summaries that are completed rapidly (i.e., in 4–12 weeks or less) with succinct, easy-to-grasp conclusions with practical guidance for action even if the evidence is weak or inconclusive, and layered information presentation.
- Partnerships and reciprocal trust are essential for collaboration between evidence synthesis producers and health systems.
- For evidence to be believable and implementable by a health system, evidence synthesis producers should present it with the local and operational context in mind.

## The Learning Health System Context

Much of the discussion about learning health systems focuses on the tremendous amounts of data each system can generate from patient encounters, including genomic data.^54^ In addition to using data within an individual system, learning health systems are forming data networks with a goal of generating new knowledge across organizations. However, there is clearly a role for synthesized external evidence in promoting the learning process. As described in one of the reports in the IOM series on learning health care systems, “A learning health care system depends on evidence to promote improvements in care delivery processes and patient care and overall system improvement. Consequently, health researchers are critical partners in generating knowledge on the effectiveness and value of interventions and care protocols.”^55^

McGinnis, writing about the application of evidence-based medicine to learning health systems, describes a process in which systems with effective clinical data systems capture patient outcomes resulting from “best practice” and feedback the lessons to generate new knowledge that will facilitate customization for individual patients.^1^ This interaction between external and internal evidence is critical in learning health systems. This echoes what we heard from our health systems’ experts, who clearly differentiated between external evidence (i.e., from the research literature) and internal evidence (derived from the system’s own electronic health records or other local datasets) and expressed the need for both types of evidence. External evidence can provide the overarching comparative effectiveness inferences with strength of evidence (SOE) ratings, whereas internal evidence is useful to contextualize the external evidence and aid in its implementation. Internal evidence may also help fill the research gaps of external evidence. Mitchell 2010, writing about the Penn Medicine CEP has described their experience gathering external evidence and supplementing with collection of local evidence and contextual information from the health system.^56^

In a workshop held by the IOM on “engineering a learning healthcare system,^55^ Brent James described the process for integrating evidence into clinical care at Intermountain Healthcare. After identifying high priority clinical processes, defined by volume and risk to patients, the organization charges teams with developing evidence-based guidelines that can be embedded in the clinical workflow. Intermountain is able to measure variance from these “shared baselines” which is used to understand the degree of variation based on patient factors versus professional factors. He noted that typically 5 to 15 percent of the content of these protocols is routinely adapted to meet the needs of individual patients, an approach known in quality theory as “mass customization.” Evidence synthesis producers could collaborate with health systems to help to summarize evidence for such protocols. After implementing protocols, health systems could provide data back to evidence synthesis groups for analysis of variations and updating of the evidence with this internal evidence as well as more recently published external evidence.

Even sophisticated health systems may need assistance identifying best practice. For example, Raymond Baxter of Kaiser Permanente described an effort to gather input from clinical leaders in the Kaiser health system to find the questions for which they needed answers to meet the “triple aim”: (1) Improving health care for individuals along six dimensions [safety, effectiveness, patient-centeredness, timeliness, efficiency, and equity]; (2) Improving the health for populations by attacking causes of ill health such as poor nutrition, physical inactivity, and substance abuse; and (3) Reducing, or at least controlling, the per capita cost of care.^57^ He received 342 questions from across the organization. Baxter was surprised to learn that “between 25 and 30 percent of the questions already had answers, though the evidence was not known or available to those who proposed those questions.”^58^

One mechanism for delivering evidence-based guidance at the point of care is clinical decision support. Collaborations between evidence synthesis programs and clinical decision support developers are important for understanding the best ways to deliver syntheses for this purpose. Guideline syntheses, in which different approaches to care of patients with similar conditions are analyzed and harmonized alongside current evidence, may be useful products for this purpose. Another possible strategy is synthesis of evidence to inform quality or performance measures. In either case, feedback from health systems to evidence synthesizers about the outcomes of care would be critical for real improvements in patient care.

The belief that evidence synthesis producers only consider randomized controlled trials conducted in highly selected populations was noted in the literature and in discussions with the health system experts. The EPC Program, like other evidence synthesis programs, has called for inclusion of nonrandomized studies and other observational studies as a matter of course.^59^ Unfortunately, the perception persists that evidence syntheses are unlikely to address “real world” situations. The Program has recently invested in methods development for evaluating complex multicomponent interventions,^3–9^ much of which is applicable to the concerns of health systems. Other work has addressed ratings of SOE for complex interventions^60^ and for synthesizing evidence when meta-analyses are not possible;^61^ both scenarios are common for interventions considered by health systems. Other authors have provided similar arguments suggesting that a broad definition of evidence including observational studies is necessary for external evidence to be used in system level decision making;^62^ and attributing the lack of use of evidence by system level decisionmakers to the historical focus of evidence producers on individual clinicians’ needs (as opposed to operational, delivery and policy needs).^63^

In describing core features of the learning health system envisioned by the IOM Roundtable on Evidence-based Medicine, McGinnis discusses the need for a “trusted scientific intermediary” that can “broker the perspectives of different parties” in determining what constitutes best practice and how such evidence should be interpreted and applied.^1^ This echoes the point made by our stakeholders that health systems need assurance of the trustworthiness of both the evidence and the evidence synthesis producers.

Although the full series has not yet been published, Harris and colleagues at the Australian public health system, Monash Health, have begun to report their experience with such a process. This health system, which includes six hospitals and multiple outpatient and long-term care facilities, operates under a state determined fixed budget. In response to economic pressures, the Monash Health Centre for Clinical Effectiveness (CCE), an Evidence Based Practice (EBP) Hospital Support Unit, undertook the Sustainability in Health care by Allocating Resources Effectively (SHARE) program to approach disinvestment in practices that are unsafe, inefficient, ineffective, or less effective than alternatives. This series of publications describes the steps taken by the system to identify opportunities for change, develop proposals for supporting the change, implement the proposals, and evaluate the extent and impact of the change. The authors state “Each step is underpinned by the principles of evidence-based practice to ensure that the best available evidence from research and local data, the experience and expertise of health service staff and the values and perspectives of consumers are taken into account.” Although authors do not use the term “learning health system” in the papers, it is clear that the goal of the project is to create a system that implements evidence, learns from the implementation, and feeds that learning back into the system and larger health care community.^25, 64, 65^

In summary, gaps exist between the needs of health systems and traditional evidence synthesis products in terms of topics covered, formats in which the synthesis is presented, and time for production. Evidence synthesis programs can support health systems by providing rapid, focused and layered summaries, addressing a broad range of topics of relevance to health systems, and by including contextual and operational evidence from local sources when available. Evidence synthesis producers need to strengthen their partnerships with health systems to better understand their evidence synthesis needs and to determine the most appropriate synthesis products for particular systems and decisions. We have proposed a framework to facilitate discussion to this end.

Based on our review and interaction with stakeholders from health systems, we next offer several recommendations for how the AHRQ EPC Program can better support health systems’ uptake of evidence.