# Appendix C Evidence Tables

Appendix Table C-1 Studies describing types of questions and decisions for which health systems require evidence

First Author, Year | Setting | Findings
Bambra 2010^68^ | UK public health system | Rapid narrative reviews followed by consensus process; - How to address inequalities/disparities in public health initiatives
Barbieri 2009^24^ | UK | Descriptive study comparing different HTA processes; - Identify appropriate comparators and patient subgroups relevant to the health system; - Independent assessment of manufacturer claims
Chambers 2016^54^ | U.S. | Commentary: notes need for evidence to inform precision medicine initiatives and implementation strategies in learning healthcare systems
Crites 2009^26^ | U.S. (academic medical centers) | Framework (review and consensus); - Patient care decisions; - Work process decisions; - Decisions about new service lines or community programs
Cumpston 2012^31^ | Australia | Source: Annual reports; - hospital demand management; - safety and quality of hospital care; - workforce recruitment and organization; - complex disease pathways (mental health, cancer, chronic illness); - rural service delivery; - native peoples’ health; - lifestyle interventions to reduce population level risk; Source: Survey of policymakers (after excluding topics on single conditions); - Professional interventions – clinical networks’ impact on quality outcomes; - Financial; ○ Provider focus – effects of funding models on quality and access in rural settings; financial incentives impact on hospital performance; regional vs. national management of health budgets impact on efficiency/effectiveness; - Organizational interventions; ○ Provider oriented – advance practice roles (paramedics, rapid response teams, allied health), hospitalists; recruiting minorities into health workforce; workplace safety; support to providers in rural areas, use of locum tenens staff; interventions to improve cultural appropriateness;; ○ Patient-oriented – interventions to improve access for prisoners, refugees; appropriate follow up to screening tests; community engagement in health service planning and delivery; ○ Structural interventions – predicting demand, determining health priorities for population health; interventions to improve planning for workforce needs; care coordination; ○ Regulatory – effects of credentialing of health professionals on safety and quality; coordination of across payment systems
Gagnon 2014^21^ | Hospital-based HTA units | Systematic Review – 34/43 units stated HTA used for technology acquisition decisions; - Standardize products; - Budget allocation, investment decisions; - Preparation for negotiations; balance manufacturer/vendor perspectives; - Address overutilization
Gallego 2008^20^ | Australia | Interviews with managers and clinicians; - New technology acquisition (includes programs, procedures, drugs, devices and equipment)
Gurtner 2014^32^ | Global | Review of work by Ciccetti 2008, interviews; - Patient safety; - Effectiveness; - Budget impact; - Cost-effectiveness; - Usability; - Organizational impact [“organizational impact criterion, which was defined as the sum of all of the necessary changes in the areas of infrastructure, human resources, training, and organizational routines”]; - Demand for treatment; - Ethical issues; - Patient perspectives
Gutowski 2011^23^ | U.S., Academic medical center-based HTA unit | Descriptive study; - Technology acquisition decisions
Harris 2017^25, 64, 65^ | Australia, large health system, publicly financed with state determined fixed budget | Description of implementation of the Sustainable, Effective and Appropriate model of change in health services; - Identifying the need for change; - Developing a proposal to meet the need; - Implementing the proposal; - Evaluating the extent and impact of change; Specific example described is disinvestment of practices that are; - Unsafe; - Ineffective, or less effective than better alternatives; - Inefficient; Method involves integrating external evidence and local internal evidence, supported by an Evidence-based Practice Hospital Support Unit within the system (several papers still in press at time of writing this report, including a paper on the role evidence synthesis)
Jackson 2013^69^ | U.S. (VHA) | Descriptive (quality improvement collaborative within VHA); - Evidence to inform quality indicators for assessing (and improving) quality of care
Jayakumar 2016^18^ Mitchell 2011^22^ Umscheid 2010^19^ | U.S., Academic medical center-based HTA unit | One case report, one commentary, and one descriptive study including an institutional survey; - Identifying best practices for institutional decisionmaking; - Decisionmaking includes formularies, supplies, and process of care; - Implementation through quality improvement and computerized decision support initiatives
Kidholm 2015^15^ | Europe | Interviews with hospital managers:; - Economics; - Clinical effectiveness; - Safety; - Health problems; - Organizational aspects; - Political and strategic information; - Ethics; - Nature of treatment; - Social aspects; - Legal information
Lavis 2010^11^ | Canada, Europe, U.S. | Review of 223 HTAs from agencies in Canada, Europe and U.S. serving different health system levels (national, provincial and organizational); - Topics to inform policymaking within health systems: “which programs, services, drugs and devices to fund”; - Topics to inform policymaking about health systems: “governance, financial and delivery arrangements within which clinical [and public health] programs and services are provided”; - Assessments of local professional, social, political, legal and ethical considerations; - Context-specific actionable messages
Luce and Brown 1995^17^ | U.S., Hospitals, Hospital systems, Health Maintenance Organizations, Group Purchasing Organizations, Public and private payers | Survey of hospitals, HMOs, public and private payers, GPOs; - Purchasing; - Controlling costs; - Marketing; - Avoiding early obsolescence; - Coverage; - Determining appropriate/standard care
Luce and Brown 1995^17^ (continued) | U.S. | Topics selected based on; - Cost; - Marketing; - Strategic planning; - Legal defense (coverage appeals); - Provider demands; - Patient requests; - Legislative activities
Makkar 2015^13^ | Australia | Framework for use of evidence; identified categories of decisions for which evidence is relevant (using self-assessment instrument and conjoint analysis); - What issues should we prioritize and what actions should we take to address identified issues?; - What are new ideas, understandings or concepts that can clarify thinking about an issue?; - How can we gain support for decisions already made?; - How can we respond to organizational or legislative requirements?
Moat 2013,^70^ Wilson 2013;^71^ Lavis 2015^72^ | Canada | Topics cataloged for the Health Systems Evidence Web site:; - Delivery arrangements; - Implementing change; - Governance; - Financial arrangements
Ølhom 2015^14^ | Europe | Systematic review of studies of information needs of hospital managers (informed questions for Kidholm 2015 interviews); - Political and strategic; - Clinical effectiveness; - Costs and economic evaluation; - Organizational; - Health problems and use of technology; - Safety and legal issues; - Technical characteristics of technologies; - Social; - Ethical
Parker 2009^36^ | U.S. | Interviews with VHA executive level policymakers and their staff suggested need for other types of evidence beyond randomized trials, such as case studies and patient preference studies.
Peterson 2016^28^ | U.S. VHA | Survey of VHA leaders on their use of Evidence Synthesis Program’s Rapid Reviews on policy or organizational and managerial system topics or process of care topics:; - Responding to regulatory and policy directives; - Developing and evaluating programs; - Determining implementation strategies; - Identifying future research needs
Smith 2009^30^ | Canada (British Columbia) | Forums of health care managers and researchers; - Deciding how to decide; - Identify “disinvestment opportunities”; - Evaluating priority setting process
Xie 2011^29^ | Canada | Perspective on HTA in Canada; - Implementing new technologies

Appendix Table C-2 Studies examining types and formats of evidence synthesis products used by health systems’ decisionmakers

First Author, Year | Setting | Findings
Hartling 2017^10^ Hartling 2015^33^ | U.S. | Interviews; - Rapid responses, rapid reviews seen as helpful to health system decisionmakers; - Credibility of review producers, relevance of key questions, close-working relationship with producers critical to decisionmakers
Jayakumar 2016^18^ | U.S. | Descriptive analysis of a hospital evidence-based practice center database of rapid systematic reviews since center’s inception (July 2006–June 2014), and survey of report requestors from the last 4 fiscal years.
Lavis 2009^73^ | Canada, Europe | Expert perspectives -Supporting Policy Relevant Reviews and Trials (SUPPORT); - Developing policy briefs to inform policy deliberations
Lavis 2010^11^ | | Interviews; - “Graded entry” to the health technology assessment – key messages needed for decisionmaking, short plain-language summary; prominent headings to make it easier to scan for information; - Followed by brief executive summary including benefits, harms costs, uncertainty, subgroup information; applicability information; - Followed by full report (25 pages); (make a longer technical report available if necessary)
Mitchell 2011^22^ | U.S., Academic medical center-based HTA unit | Descriptive study; - Evidence inventories/rapid reviews produced internally or using external sources
Murthy 2012^50^ | Canada, Europe | Systematic review:; - Distribution of bulletins based on systematic reviews associated with practice improvement
Peterson 2016^28^ | U.S. (VHA) | Survey of VHA leaders on their use of Evidence Synthesis Program’s Rapid Reviews on policy or organizational and managerial system topics or process of care topics:; - High level of agreement that the reviews influenced the delivery system; - High level of agreement that reviews placed the evidence in context for the VA system
Petkovic 2016^49^ | Canada, Europe, U.S., Africa, Asia | Systematic review of studies of derivative products from systematic reviews for policymakers and managers; - Two studies assessed the use of different formats of evidence summaries in decision-making and found little to no difference in effect; - Four studies found little difference in effect of different summary products for knowledge, understanding or beliefs; - Three studies found not difference in usefulness or usability; - Summary of findings tables were easier to understand compared to complete systematic reviews. Participants preferred tables including study event rates and absolute differences
Wye 2015^35^ | UK | Interviews, observation of policymakers:; - Preferred verbal presentation;; - Preferred inclusion of local information;; - Preferred simplified and brief documents

Appendix Table C-3 Studies describing tools for considering or promoting the use of evidence in health system decisionmaking

First Author, Year | Setting | Findings
(Anonymous) 2010^74^ | U.S. | Commercial online tool; - For using evidence to create locally and collaboratively developed but standardized order sets
Aicken 2012^51^ | U.K. | Decision analytic modelling; - At the local level for decisions about service delivery
Boyko 2015^75^ | Canada | Review of Evidence Informed Health Policymaking (EIHP) in Canada (uses language from Ellen framework below); - Examples of “push” efforts; - Examples of “pull” efforts; - Examples of “linkage and exchange” efforts
Catallo 2014^40^ | Canada | Psychometric study of instrument for assessing organizational capacity for using evidence in decisionmaking; - Culture and values supporting use of research evidence in decisions; - Setting priorities for obtaining research evidence; - Ability to acquire research evidence (access to resources); - Capacity to assess quality and applicability and to interpret results; - Use of research evidence to inform recommendations; - Monitoring and evaluation of policies and programs; - Continuing professional development on evidence-based topics
Ellen 2014a,^45^ 2014b,^46^ 2013^47^ | Canada | Interviews, seven domain framework for promoting knowledge translation in health system decision making; - Establishing a climate where research evidence is used in decisionmaking; ○ Creating formal accountability for use of evidence; ○ Include use of research evidence in decisionmaking in the organization’s mission, vision, values and strategic planning; - Production of timely and relevant research by researchers and funders; - “Push” efforts by librarians or knowledge brokers to disseminate research evidence to potential users; - “Facilitating pull” efforts by health system to ensure appropriate infrastructure is in place for knowledge users to have access to research evidence; - “Pull” efforts by health system decisionmakers to enable appropriate use of evidence; - “Linkage and exchange” efforts facilitating relationships between researchers and knowledge users; - Evaluation of knowledge translation efforts; Barriers to use of evidence in health system decisionmaking; - Limited resources; - Time constraints; - Negative attitudes toward change; Facilitators; - Genuine interest from health system decisionmakers; - Two-way communication between researchers and decisionmakers
Gagnon 2014^39^ | Multiple | Systematic review of instruments to assess organizational readiness for knowledge translation in health care identifying 26 instruments.
Gifford 2014^42^ | Canada | Evaluation of organizational strategies to promote evidence informed decision making by nurse managers and clinical leaders in home health care. Research questions: What organizational structures and processes facilitate and support EIDM by managers and clinical leaders? What are the barriers and enablers to influencing EIDM?; - Intervention included an interactive educational workshop, evidence facilitators, library services, information sharing, and encouragement and recognition.; - Participants reported having more resources to conduct research, having relevant staff to contribute to EIDM, receiving more feedback and rationale on decisions, and being more informed about how evidence informed decision making in the organization.
Goeree 2009^76^ | Canada | Description of the Ontario HTA process; - Health care facilities, community-based health service providers or the Ministry of Health and Long-Term Care request the HTAs; - Uncertainty after HTA completion may be addressed through field evaluations (similar to coverage with evidence development); - An economic model is developed comparing the technology and alternative strategies; value of information analysis performed to determine feasibility and design the field evaluation study; - Study results placed in context with HTA (literature review)
Goetghebeur 2008^52^ | Canada | Framework for presenting evidence to facilitate decisionmaking in which scientific judgments are separated from value judgments; - Used Multicriteria Decision Analysis (MCDA) for clarifying value judgments; - Developed a Value Matrix encompassing quality of evidence, impact on disease, economic impact (budget impact analysis)
Innis 2015^48^ | U.S. | Scoping review (1991 – 2014) – 30 studies examining barriers and facilitators to use of evidence in health systems. Identified themes; - Process organizations use to select evidence-based practices for adoption; - Use of a needs assessment; - Linkage to the organization’s strategic direction; - Organizational culture; - Organization’s internal social networks; - Resources (including education and training, presence of information technology, financial resources, resources for patient care, and staff qualifications); - Leadership; - Presence of champions; - Standardization of processes; - Role clarity of staff; - Presence of social capital
Lavis 2015^77^ | Canada | Descriptive Creation of the healthsystemsevidence.org Web site to provide health systems with easy access to evidence on; - Governance arrangements; - Financial arrangements; - Delivery arrangements; - Implementation strategies; - Provider types; - Disease areas; - Settings
Lefebre 2010^41^ | Canada | Case study using an organizational self-assessment tool; - Found that use of evidence in management decisionmaking was sporadic at baseline; - Barriers identified; - Interventions targeting barriers designed and carried out over 18 months; - Evaluation at 1 year post-implementation showed increased use of evidence; - Provides a list of key steps for other organizations to use
Makkar 2015^13^ | Australia | Survey – used conjoint analysis to develop a framework; used the Staff Assessment of enGagement with Evidence from research (SAGE) and created a scoring system.; - Results of the assessment can assist organizations in improving use of evidence
Munn 2014^53^ | New Zealand | Description of scoring method; - Using HTA and cost information with input from local stakeholders about expected changes in outcomes and costs with alternative choices
Perrier 2011^43^ | Canada | Systematic review identified a single cross-sectional study in 3 publications and one RCT (Dobbins 2009) examining interventions to increase use of systematic reviews in decisionmaking.; - The strength of evidence was judged to be weak for determining whether any of the interventions were effective (access to a repository; repository plus tailored messages; repository, tailored messages and a “knowledge broker”)
Ritrovato 2015^78^ | Europe | “Decision-oriented HTA”; - Integrates multi-criteria decision analysis (MCDA) into HTA using the analytical hierarchy process (AHP)
Williams 2015^79^ | Australia | Scoping review on organizational barriers to use of evidence (49 articles included in this study, there were 29 cross-sectional surveys, 6 descriptions of specific interventions, 7 literature reviews, 4 narrative reviews, 9 qualitative studies, 1 ethnographic study and 1 systematic review). Major barriers were; - Workload; - Other staff/management not supportive of EBP; - Lack of resources; - Lack of authority to change practice; - Workplace culture resistant to change
Wilson 2013^71^ | Canada | Meta-review based on Health Systems Evidence Web site; - Describes the content of systematic reviews on health system topics available through the Web site, their quality and recency; - Describes availability of user-friendly summaries