# Appendix B Initial Framework

Figure B-1 Preliminary framework for understanding evidence needs of health systems

ACO=accountable care organization; EHR=electronic health record; EPC=evidence-based practice center; GPO=group purchasing organization; PPI=physician preference items

This figure shows a preliminary framework for understanding evidence needs of health systems. A large box contains questions about the evidence such as what type of question, what type of decision, what type of evidence need, and what impact the EPC program had on these questions. Arrows emanate from this box lead to 3 boxes that suggest stratifying the questions by system type, participation of the system in different financial and structural payment agreements and whether the system has established processes for evidence synthesis and translation.