# Appendix A Search Strategy

## Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) 1946 to Present

Date Searched: April 7, 2017

Searched by: Robin Paynter, MLIS

1 | “Decision Making, Organizational”/ or *Decision Support Techniques/ or “Delivery of Health Care”/ or “Delivery of Health Care, Integrated”/ or *Diffusion of Innovation/ or *Efficiency, Organizational/ or *Health Policy/ or *Health Planning/ or *Health Priorities/ or *”Models, Organizational”/ or *Organizational Culture/ or *Organizational Innovation/ or *Organizational Objectives/ or *Organizational Policy/ or *”Outcome Assessment (Health Care)”/ or *Planning Techniques/ or *”Process Assessment (Health Care)”/ or Quality Improvement/ or “Quality Indicators, Health Care”/ or Value-Based Purchasing/ | 228308
2 | Academic Medical Centers/mt, og or Accountable Care Organizations/mt, og or *Chief Executive Officers, Hospital/ or *Health Facility Administration/ or *Health Facility Administrators/ or Health Services/mt, og or Health Services Administration/ or *Health Systems Agencies/ or *Hospital Administration/ or *Hospital Administrators/ or exp *Hospitals/mt, og or *”Organization and Administration”/ or *Policy Making/ or Provider-Sponsored Organizations/mt, og or (administrat* or leader* or manager* or decision-making or decisionmaking or decision-maker* or policymaking or policymaker* or policy-maker* or learning-health*).ti,kf. | 258945
3 | Meta-Analysis as Topic/ or Review Literature as Topic/ or Health Services Research/ or Technology Assessment, Biomedical/ or Cost-Benefit Analysis/ or Evidence-Based Medicine/ or Evidence-Based Practice/ or “Practice Guidelines as Topic”/ or Guidelines as Topic/ or (guideline* or review* or synthes* or meta-analys* or evidence* or HTA* or technology assessment* or implement* or facilitator* or barrier* or “information need*”).ti,kf. | 1288836
4 | and/1–3 | 3748
5 | 4 not Shared Decision-Making.ti,kf. | 3675
6 | limit 5 to (english language and yr=“2007 -Current”) | 1553