# Recommendations

Each of the six participants provided recommendations during her/his individual interview on how to best engage patients, caregivers, and patient advocates in systematic reviews. At the completion of the individual interviews, all of the recommendations were compiled and duplicate recommendations deleted. Although there were a few recommendations that were made by a single participant, the vast majority of the recommendations were made by multiple participants; there was remarkable consistency across the six participants.

The compiled recommendations were organized into themes within a single document, which was emailed to the participants for their review prior to the focus group discussion. The list of recommendations was then discussed extensively during the focus group discussion, and some additional recommendations were added to the list. Every one of the recommendations listed below was suggested by one or more participants, and every recommendation was discussed by the group. There was no disagreement among the six participants about these recommendations.

## Patient KI Recruitment

1. Do not ask a patient/patient advocate to participate unless the EPC is truly interested in and ready for a patient/patient advocate perspective. Do not involve a patient/patient advocate simply because AHRQ requires EPCs to do so. Some of the participants felt they were asked to do so in order to “fulfill a requirement” and that the EPC was not truly interested in their perspective.
  - “You do get the feeling that you're just kind of an afterthought or you've been put on this because that's a requirement…. It seemed like they had not really thought through what our role in all of this is.”
2. When recruiting patients/patient advocates from patient advocacy and other organizations, provide sufficient detail to allow the most appropriate individuals to be selected to participate in the systematic review. Additionally, conduct an initial screening process to ensure that the patient/patient advocate has the experience/knowledge required to answer the target questions and is the correct “match” for the systematic review. Do not waste a patient/patient advocate's or an interviewer's time. One KI suggested that a brief screening questionnaire be sent to the patient/patient advocate to ensure that the person has had the relevant experiences needed for the systematic review (e.g., do not invite a patient to answer questions about his/her experience with treatment if his/her disease was never treated).

## Preparation of Patient KIs to Participate in Systematic Review

1. Inform the patients/patient advocates why they were chosen to represent patients and why their participation is so important. Explain how important the patient perspective is, why the person has been chosen, and why this group of Key Informants has a patient in it and the important role that a patient plays in this process. Say something to the effect of “we value your voice in the discussion,” and “we want you to use it during this call.” This will help empower the patients/patient advocates to participate more fully.
2. Provide clear expectations for the patient/patient advocate's role. Indicate whether they are there to discuss their personal experiences with the disease/condition or as a representative of the larger group of patients with the disease/condition. Indicate the specific questions that they, as patients/patient advocates, will be asked, so they can prepare themselves for the discussion and feel they are making a significant contribution.
3. Educate the researchers and clinicians about the important role that patients/patient advocates play and the valuable contributions they can make to the discussion. Unless researchers and clinicians understand what patients/patient advocates bring to the table, they are likely to be dismissive and discount what the patients/patient advocates say.
4. Provide easy-to-understand information to the patient/patient advocate prior to the call about: (1) the mission of the AHRQ and EPCs, (2) the overarching goal of the systematic review and group stakeholder discussion, (3) what will transpire before, during, and after the interview/group stakeholder discussion, (4) the issues that will be discussed during the interview/group stakeholder discussion, (5) what her/his role is as a patient/patient advocate, (6) what s/he should be prepared to discuss (e.g., specific questions), and (7) who will be on the call (i.e., name and background) and the role of each of those individuals in the group stakeholder discussion. Everything needs to be spelled out in a clear, easy-to-understand way. There should be no confusion about what is involved in participating in a systematic review; KIs should understand each step of the process. Providing a brief bio for each of the individuals who will participate in the group stakeholder discussion helps orient the patients/patient advocates as well as the clinicians/researchers. It is very common for the researchers and clinicians to run in the same circles and know each other, whereas the patient/patient advocate is unlikely to have this baseline relationship, which can cause her/him to feel like an outsider during the discussion. Providing some background information on everyone in the group helps to minimize that sense of alienation. Informing patients/patients advocates about the format of the discussion and what they should be prepared to talk about allows them to prepare for the discussion. Understanding what questions will be asked of them is very important for engaging the patients/patient advocates, minimizing their anxiety, increasing their self-efficacy, and having a productive discussion with them. Ideally, there should be an agenda provided prior to each discussion/meeting, and minutes provided afterwards.
  - “If they did… a preview before the call to set that up and say: ‘Here's what will occur. Here's the background of the people that will be on the call. Here's what they will address, and here's where your input would be valued in the following way, or here's what we want to hear. Here's the questions that are likely to come up.’ Not to have it absolutely highly scripted, but to have that expectation a little bit more out on the table.”
  - “Every call we had, there was an agenda…. Had agendas for everything. We knew exactly what the meeting and the call was going to be about - some of the questions that were going to be asked…. All of them were well-organized, and you weren't left not knowing what's taking place, and since that meeting, I will tell you, we've had ongoing communication. Like this is where we are now and this is what's happening.”
5. Provide a layman's summary of the studies being discussed prior to the call. The articles themselves may be too technical for some of the patient/patient advocates so scientific information needs to be provided in terms that are less technical and easier to understand. It can be overwhelming and intimidating for some people to read highly technical information prior to the discussion, and fear of appearing stupid or uninformed can discourage people from participating. For those who are more experienced at reading and understanding scientific information, links can be provided to the actual studies and more detailed information. Because patients and patient advocates have a range of backgrounds and expertise, it is important to provide easy-to-understand information with the option to read more technical information, if they so desire. Some of the participants suggested that KIs with greater medical expertise might find participating in the group stakeholder discussion “less inviting” if the information is “too basic.”
6. Have a member of the EPC contact the patient KI after the information about the upcoming discussion is sent out to ensure that the person understands what was sent and to answer any questions prior to the call. Although emailing information may be sufficient for some, there are others who would prefer to speak with someone over the phone. At the very least, the KI should be provided with a contact person whom s/he can reach out to with any questions.

## Selection of Facilitator With Strong Communication Skills

1. Select a facilitator who has “really good communication skills.” The facilitator is key to the successful engagement of patients, caregivers, and patient advocates in a discussion. Effective facilitation requires a certain set of skills and not everyone has those skills, although they can be learned. Many of the facilitators are chosen for their technical expertise in meta-analyses, meta-regression, patient statistics, and/or other scientific concepts, rather than for their facilitation skills. Just because someone has expertise in a particular health condition or is a researcher does not mean s/he knows how to engage people in a group discussion.
  - “I mean these were great researchers, but their communication skills were really flat lining.”
  The facilitator must have strong communication skills, take an active role in managing the discussion, and ensure that everyone has the opportunity to contribute and feels that her/his input is valued. This individual must be aware of who is on the call and actively engage the patients/patient advocates by directly asking them questions that are specifically relevant to them. The discussion needs to have structure but also flexibility so that people can also make contributions spontaneously. An effective facilitator (1) ensures that the questions are clear and relevant, and allows sufficient time to answer the questions, (2) makes sure that the patients/patient stakeholders feel relevant and valued, (3) is active in controlling the discussion and does not allow anyone to monopolize it, and (4) ensures that all voices are heard and that everyone is treated with respect and is not dismissed or denigrated. This does not mean that every aspect of a group KI discussion requires patient/patient advocate input, but they should know they are free to contribute, and their feedback should be directly solicited during pertinent portions of the discussion.
  - “I think it behooves people who are conducting the interview to have some really good responses that let the person who is responding know that no matter what they say, their responses are respected…. Sometimes it felt to me on different calls like I dropped a penny in the well and never heard a response. And sometimes that almost feels like a judgment…. Hearing a response or some kind of ‘I'm glad you mentioned that’ or ‘Thank you for your input’ or ‘That's important to us’ – some set of stock phrases that could really communicate that human dimension of gratitude.”

## Structuring Group Stakeholder Discussion To Maximize Patient KI Involvement

1. Be flexible and not overly structured when interviewing a patient/patient advocate. Listen carefully to what the patient/patient advocate is saying, and do not adhere to a rigid question protocol (script) if it does not apply. Not only can rigid protocols be frustrating when there is a mismatch, they can also result in important information being missed. If the questions are not relevant to the patient/patient advocate, either modify the questions or end the interview with the patient/patient advocate. Do not waste the patient/patient advocate's or the interviewer's time.
2. Structure calls so that patient/patient advocates know when and what they have to contribute. The scientific/technical portion of the discussion can be overwhelming for many patients/patient advocates. Bring patients/patient advocates into the discussion when it is relevant to them, and present information in layman's terms. There can be a portion of the call devoted to patient/patient advocate input, a portion of the call that is highly scientific, and a portion where there is overlap. Patients and patient advocates can drop off from the portion of the call that is science-based and technical. Be sure to allocate a dedicated period of time for patient/patient advocate input. At the start of the call, inform patients that a portion of the call will be highly technical, and they are welcome to remain on the call or they can leave the call; it is up to them. Because patient/patient advocates have different levels of knowledge and expertise, do not assume that they cannot participate in the technical portion of the discussion.
  - “I think when it's so scientific, I think there needs to be a better set up or thoughtfulness in using folks' time to sit in on these calls. I think there's some value to having us on, but not when it's specifically science and we can't add to that…. Maybe there's some overlap where you need both of us, and there's specific time devoted to the patient advocate and the patient. And then there's specific science-based, and you don't need the patient advocate or the patient; maybe then they drop off the call…. I think there's some value of having everybody participate and hear each other, though.”
  - “I have a unique situation in that I have both a scientific and medical background…. The call I was on, I was knowledgeable of the disease and although sometimes the science was a little bit beyond the scope of my background, I didn't really feel intimidated or at a loss. In fact, it encouraged me to do some more reading.”
3. Carefully manage the discussion so that clinicians and researchers do not become critical of how the patients or their children were, or are currently being, treated for their health condition. Facilitators need to be sensitive to the fact that these KIs are patients and caregivers, and if the KIs hear from the clinicians and researchers that they or their children should have received different treatment, it can be stressful and upsetting for them.

## Lessening the Stress of Participating as a Lone Patient

1. Consider having a one-on-one call with the patient/patient advocate prior to the group stakeholder discussion. Being the only patient/patient advocate in a group stakeholder discussion can be daunting and overwhelming. Her/his anxiety can potentially be lessened by interviewing her/him one-on-one prior to engaging her/him in the group discussion. Another option is to have a group call with patients/patient advocates and a separate group call with clinicians/researchers prior to bringing them together for a joint call. According to the participants, it is important for clinicians/researchers to hear from patients/patient advocates, so a joint call is also critical.
2. Include at least one patient and one patient advocate in every group stakeholder discussion. Do not assume that a single individual can adequately represent an entire disease or health condition. Patients and patient advocates bring different perspectives to the discussion. Patients will talk about their own personal experience with the disease/condition, whereas patient advocates will provide a broader perspective about patients with the disease/condition. Additionally, having more than one patient/patient advocate participating in the group discussion will be less intimidating for them and encourage greater engagement and participation.
  - “I think patients should be there because hearing directly from a patient is important. But then the patient advocate/patient organization can also bring a different perspective from a general population of patients, and not just be focused on a specific type of disease…. I think they bring in different perspectives; it shouldn't just be one or the other. I think both a patient and a patient organization/patient advocate should be represented.”

## Online Videoconferencing To Increase Participation of KIs

1. Ensure that all of the KIs and the facilitator can see one another during interviews and group stakeholder discussions. Face-to-face meetings are ideal but not feasible in most cases. Second best are phone meetings with video. It is harder to become distracted and disengaged if an individual in the group can see the other participants and if s/he knows that others can see her/him. It is too easy to focus on other tasks (e.g., reading emails) if the discussion is conducted via audio only.
  a. “I think that video [WebEx] would be a lot more helpful because putting a face to what people are saying is helpful. It makes you feel more engaged; it makes you feel more part of the conversation.”

## Followup With KIs After Group Stakeholder Discussion To Keep Them Engaged

1. Follow up with the patients/patient advocates after the group stakeholder discussion. Provide them with a timeline so they know when they can expect to hear from an EPC staff member again. Do not leave them in the dark for months at a time.
  a. “I think follow-up calls or a follow-up email that says, ‘A report is coming’ or ‘We're interested in your feedback on the report,’ I think that is helpful. The feeling that it is not a ‘one-and-done’ kind of moment, and you have some kind of continuity where you see that what you said or what you're involved in is going someplace, has gravitas going forward, that something is going to be made of your participation as part of that group.”
2. Consider providing minutes after every call/meeting. This allows KIs to check to see if their contributions are accurately represented, and it also gives them the opportunity to review what occurred and follow up with questions or additions. Along with the minutes, provide the name and contact information of someone at the EPC they can reach out to if they have additional questions/comments or feel that their perspective was not accurately reflected in the minutes.
3. Provide a copy of the draft report to the patients/patient advocates who participate in the group stakeholder discussion, and actively encourage them to provide feedback on the report. Patients/patient advocates will not be motivated to read the draft report unless they feel actively engaged in the group stakeholder discussion and believe that they made a meaningful contribution. Consider having a second call to review the main recommendations of the report and ensure that people's perspectives have been accurately represented.

## Outreach to KIs To Disseminate Findings From Evidence Report

1. Consider following up with patients/patient advocates to indicate how the information provided in the final report is eventually used. Patient KIs indicated a great interest in knowing what happened to the final report in which they participated and whether it has had any practical, real-world impact. They stated that patients/patient advocates will be much more inclined to get involved in this process if they believe that their participation will make a difference. In other words, patient KIs want to know, for example, if the information in the report impacts how treatment is provided in the clinical setting. Does it affect how clinicians are treating patients? The participants were not entirely clear on who should follow up with and provide this information to patient KIs, but there was some discussion about AHRQ doing it.
  - “If you felt, as a patient, that your input may have resulted in an element or a part of a course of action, you could feel that you really did have a sense of contribution to an important area.”
2. Consider providing an opportunity for patient advocates to disseminate the recommendations/findings in the report to patients, their families, and other stakeholders. Patient advocates are very invested in providing information to others, and they are a mechanism for distributing the report more broadly to those who will make use of it. As AHRQ strives for greater dissemination of the knowledge gained from EPC reports, patient advocates who are prominent in their organizations can be internal champions if they feel engaged and relevant during the process.