# Purpose

The Agency for Healthcare Research and Quality (AHRQ) wants to better understand the ways in which patients, caregivers, and patient advocates are being engaged in systematic reviews. Consequently, in April 2016, they conducted focus groups with Evidence-based Practice Center (EPC) personnel who have facilitated group stakeholder discussions. While the focus group discussions were robust and helped elucidate some successful practices and barriers, it was felt that talking directly with the patients, caregivers, and patient advocates who had previously served as Key Informants (KIs) would be critical to establishing best practices. Consequently, the main objective of this project was to examine how patients, caregivers, and patient advocates who participated as KIs in systematic reviews regarded that experience and what their recommendations are for improving that process.