# Procedure

At the spring 2016 EPC Program meeting, the University of Connecticut (UConn) EPC team introduced this quality improvement project to the other EPCs, including its purpose and the need for patients, caregivers, and patient advocates who could provide honest feedback about their experiences as a KI. EPCs were informed that with the variety of approaches used to engage KIs, this was an opportunity to assess how KIs were being involved in systematic reviews and solicit their recommendations for quality improvement.

On September 8, 2016, AHRQ reached out to EPC Program contractors via email to get recommendations for former KIs to interview (see Appendix A for the email and recruitment document). Because the UConn EPC was conducting the project, UConn was excluded from recommending KIs. Seven of 12 EPCs provided a total of 16 names of KIs and their contact information; recommendations ranged from one to five KIs per EPC.

The UConn EPC team contacted the KIs recommended by the seven EPCs. KIs from six of the 12 EPCs agreed to participate. Of the 16 KIs contacted by email, seven never responded, two indicated that they were too busy to participate, and one person was never reached because of an incorrect email address. The six KIs who participated in the project were white and primarily female (5 females, 1 male), with a mean age of 56 years. They had participated in prior systematic reviews between 2014 and 2016 that were conducted by EPCs from the Southeast (N=3), Northeast (N=2), and Midwest (N=1). The KIs were patient advocates (N=4) and caregivers (N=2). (See Table 1 below for more information).

Table 1 Demographics of Key Informant participants

DEMOGRAPHICS (N=6) | | N | %
TYPE OF KI | Patient Advocate | 4 | 67%
TYPE OF KI | Caregiver | 2 | 33%
GENDER | Male | 1 | 17%
GENDER | Female | 5 | 83%
RACE / ETHNICITY | White | 6 | 100%
RACE / ETHNICITY | Non-White | 0 | 0%
RACE / ETHNICITY | Hispanic / Latino | 0 | 0%
AGE (Mean Age = 56 years) | 35-44 | 1 | 17%
AGE (Mean Age = 56 years) | 45-54 | 3 | 50%
AGE (Mean Age = 56 years) | 55-64 | 0 | 0%
AGE (Mean Age = 56 years) | 65-74 | 2 | 33%
KI DISCUSSON FORMAT | Mixed Group | 4 | 67%
KI DISCUSSON FORMAT | Individual & Mixed Group | 1 | 17%
KI DISCUSSON FORMAT | Individual | 1 | 17%
EPC REGION | Northeast | 2 | 33%
EPC REGION | Southeast | 3 | 50%
EPC REGION | Midwest | 1 | 17%
YEAR PARTICIPATED | 2014 | 1 | 17%
YEAR PARTICIPATED | 2015 | 3 | 50%
YEAR PARTICIPATED | 2016 | 2 | 33%

Individual interviews were scheduled with each of the six KIs. Prior to the interviews, participants were provided with an Information Sheet (see Appendix B) describing the purpose of the project and procedures that would be followed. They were also asked to complete a very brief online questionnaire via Survey Monkey to collect relevant demographics information, such as age, gender, race, ethnicity, and number and location of EPC projects in which they had participated (see Appendix C).

All six KIs participated in a one-hour individual interview followed by a focus group discussion (see Appendix D for the questions asked). The interview and focus group discussion focused on the KIs' experience participating in a systematic review, including:

- How prepared the KIs felt for their individual interview with an EPC member and/or their group stakeholder discussion with clinicians and researchers.
- What the experience was like participating in the interview and/or group stakeholder discussion.
- What type of follow-up there was, if any.
- Any recommendations they had for improving the process.

The UConn EPC team facilitated the individual interviews and the focus group discussion, which were conducted via WebEx and audio recorded. One member of the UConn EPC team took notes during each session and provided a summary of the notes to the other member and two representatives from AHRQ within a few hours of completion of the session. Individual interviews occurred on the following dates:

- October 14, 2016
- December 13, 2016
- December 14, 2016
- December 19, 2017
- January 19, 2017
- December 1, 2017

The focus group discussion was conducted on March 22, 2017, it was one hour in duration, and all six KIs participated. Prior to the focus group discussion, the KIs were sent a summary of the key issues that came out of the individual interviews. This summary was created following a detailed review of the transcription of each of the six audio-recorded interviews; recurring themes were identified and included in the summary. Once completed, the KIs were asked to review the summary prior to the focus group discussion and to indicate during the group discussion whether the summary accurately represented what was discussed during their individual interviews and if there were changes or additions that needed to be made. There was unanimous agreement that the summary was an accurate representation of what they had discussed during their interviews.

The focus group discussion centered on a review of what the KIs perceived as the strengths and weaknesses of the systematic review process in which they had participated and reaching consensus on their recommendations to the AHRQ about how EPCs can best engage patients, caregivers, and patient advocates in that process. Some additional recommendations came out of the focus group discussion that were not originally elicited during the individual interviews.

Following the focus group discussion, the transcriptions of the six individual interviews and the group discussion were again reviewed in detail for recurring themes. The summary of key issues that was created following the individual interviews and focus group discussion served as the basis for the current report, with modifications and additions being made based on a comprehensive review of the transcriptions. Key findings were elucidated with representative quotes from the participants. A draft of the report was then sent to AHRQ and all six KIs for their feedback.