# Limitations

This report summarized the perceptions of and recommendations from six patient advocates and caregivers who participated in UConn EPC's quality improvement project. Although the findings were consistent across the participants, there are some limitations that should be noted:

1. Patient advocates and caregivers were interviewed from only six of the 13 EPCs, and only a very small number of the patient advocates and caregivers who were involved in the EPC program over the past several years were included. This limits the generalizability of the findings.
2. It is unclear how representative those KIs who agreed to participate are of the greater population of KIs. Those who saw the email invitation and agreed to participate might be very different from those who never responded to the email or who responded and declined to participate.
3. In addition to participating in an EPC systematic review, some of the KIs had participated in individual interviews and group discussions with other organizations, which no doubt impacted their perceptions. Because this was not systematically assessed, it is unclear in what way these other experiences influenced KIs' perceptions and recommendations.
4. Due to the small number of participants, a formal coding system and rigorous qualitative analyses were not used to analyze the data. Rather the transcripts were reviewed in detail for recurring themes and for recommendations. All recommendations were included in this report. To ensure that perceptions and recommendations were accurately represented, participants were asked to review them prior to the focus group discussion and then again in the draft report. The participants agreed with the findings as presented.
5. Some of the perceptions and recommendations elicited may not be relevant to all EPCs because of the heterogeneity in EPCs' approach to systematic reviews.

Despite these limitations, we believe that the feedback was largely consistent across the six participants, which provides greater confidence in the applicability of the findings.