# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Patrick Farrant, Karla L. Hall, Alison Kelley, Adrienne Kennedy, Pam Shlemon, and Chevese Turner. These individuals generously agreed to participate in an individual interview and a focus group discussion about how to most effectively engage patients, caregivers, and patient advocates in systematic reviews. In addition, they reviewed this report to ensure that it accurately represented their perceptions, feedback, and recommendations.