# Feedback From Key Informants

## Preparation of Patient KIs for Systematic Reviews

### Majority of KIs Reported Not Receiving Sufficient Information Prior to Discussion

There was a range of perspectives on how prepared KIs felt for the group stakeholder discussion. One of the participants stated that she “felt very prepared in terms of what [they] were going to be discussing and what [she] could contribute to that discussion.” However, most of the KIs did not feel that sufficient information was provided prior to the group stakeholder discussion about the AHRQ and EPCs, the purpose of the evidence report, the process and timeline for that report, and the other individuals who participated in that discussion. Most importantly, the majority of the participants reported that they did not fully understand their role in the development of the evidence report and were not clear on what was going to transpire during the group stakeholder discussion until they got on the call.

- “I did not feel very prepared for the group discussion at all actually. I thought there would be more parents and that there would be more of a need for me, that they were looking for my input specifically, and that I would be giving them my input and they would be working with that.”

For those who were both a patient and patient advocate, they were confused as to whether they were supposed to speak about their own experiences as a patient with the disease or represent the larger population of people with the disease.

### KIs Who Understood Each Step of the Process Felt Better Prepared for the Discussion

Participants said the information that was provided to them prior to the individual interview/group stakeholder discussion was quite variable with some individuals receiving “some general information…but no hints as to what kind of questions [they] were going to be asked.” At least one participant indicated that the document provided prior to the group stakeholder discussion was full of “lingo, scientific terminology, and technical language” that was sometimes overwhelming and difficult to understand. The KI who felt the most prepared for the discussion reported being provided with “extensive” information prior to the call that was clear and easy to understand, including a meeting agenda, a description of how the actual review would work, the type of information that was being sought, how the panel was organized, what would be discussed, and a timeline for the entire process. All of the participants agreed that it was essential for KIs to be provided ahead of time with the questions most relevant to them so that they could prepare for the discussion. They felt that this is particularly important when there is only one patient/patient advocate participating in the discussion.

- “One of the things they gave us was called ‘Considerations for Key Informants,’ which were questions and issues for the Key Informant. So for example, one of the questions was, help identify comprehensive set of critical target outcomes for treatment of [the health condition]. We were supposed to go into that, have some thoughts on that.”

## Participation in KI Interviews and Group Stakeholder Discussions

### All of the Participants Believe There is Value in Participating in Systematic Reviews

Participants' experience in systematic reviews ranged from very positive to frustrating. None of the participants, however, regretted participating in a systematic review, and all of them would do it again. Everyone believed that there was great value in clinicians and researchers hearing the perspectives of patients and patient advocates. And many of them felt that they learned something by listening to the researchers and clinicians. They commended AHRQ for requiring EPCs to include patients/patient advocates in systematic reviews.

### KIs Feel More Engaged When They Understand Their Role and Their Contributions are Valued

Those who reported the most positive experience participating in a systematic review had been well-informed about the purpose of the review and the process involved, including what would happen during and after the group stakeholder discussion (e.g., review and comment on a draft report). Their role in that process was made clear to them, which increased their self-efficacy and level of engagement. Overall, they felt valued and respected, and they believed that their contributions were viewed as important and significant. Those who had a less positive experience reported more confusion about the purpose of the group stakeholder discussion and their involvement in that discussion, and they did not feel that sufficient efforts were made to involve them in it.

Some of the participants indicated that their perspective had been solicited and their contributions were valued, resulting in them feeling comfortable talking openly and honestly during the discussion. In contrast, there were others who felt minimally relevant:

- “I'm not really sure what it was they were looking for from a patient or why I was involved. They just said they wanted to have a patient on the line…. I was never really asked to contribute except by one of the psychiatrists who said, ‘Well, we do have a patient on the call. Why don't we ask him what his experience was like?’… Except for that one guy, I wasn't really engaged in the discussion at all.”

### A Skilled Facilitator Is Key to Successful Engagement of Patient KIs

Everyone agreed that the key to successful engagement of patients, caregivers, and patient advocates is a strong, competent facilitator who works to ensure that everyone gets an opportunity to speak and contribute. According to the participants, some of the facilitators did a better job of this than others. Effective facilitators engaged both the patients/patient advocates and the clinicians/researchers, controlled the flow of the discussion so that dominant individuals did not take over and monopolize the discussion, and did not let others minimize or discount a person's contributions. In addition, effective facilitators understood what aspect of the discussion would benefit from the patient/patient advocate perspective and cued the patient/patient advocate at the appropriate time to give his/her perspective.

Facilitators who were less effective at engaging patients/patient advocates tended to direct fewer questions to the patients/patient advocates themselves and appeared to have the attitude that “whoever wanted to speak up, could,” and there was minimal effort to actively involve the patients/patient advocates. Most of the participants indicated that the facilitator “did a fine job” but could have elicited more input from patients/patient advocates by specifically asking them “what are your thoughts on this” or “do you have anything to add” and making it comfortable for them to contribute.

### Majority of Participants Voiced Frustration that Group Stakeholder Discussions were Highly Technical

All of the participants reported that there were opportunities for patients/patient advocates to speak during the group stakeholder discussions, but those opportunities tended to be limited relative to the scientific/technical portion of the discussion. A couple of the participants reported that “for the most part, [they] were heard and that many of the things [they] said were validated by others in the group.” However, some of the participants reported that the clinicians/researchers tended to talk amongst themselves during the group stakeholder discussion and did not engage the patients/patient advocates in the discussion. Some felt that the discussion was geared towards the clinicians/researchers with limited interest in the patient/patient advocate perspective. One of the participants reported feeling like an “outsider looking in.” S/he felt like the discussion was more to “benefit them” [the clinicians/researchers]. A few of the participants indicated there were some clinicians/researchers who were “dismissive” towards them. This experience was in sharp contrast to their experience in similar discussion groups sponsored by other organizations, in which there was reportedly great interest in what patients/patients advocates had to say.

All of the participants agreed that it is not a good use of a patient/patient advocate's time if the vast majority of the call is highly scientific/technical. Patients/patient advocates are interested in the science, but if it goes on too long, they can get frustrated, feel intimidated, and lose interest because they often do not understand it and cannot contribute.

- “I did not feel very prepared for the group discussion…. I wasn't prepared for such an in-depth, deep discussion that was that far over my head. There were times when I had no idea what they were talking about…. I think once I started feeling I was over my head and that they were discussing things over my head, I kind of backed down because I didn't want to say something wrong or inappropriate. …I was afraid to say something stupid.”

### Rigid Interview Protocols Can be Very Unproductive

It is also exasperating for the patient/patient advocate when the questions being asked do not pertain to her/his experience/knowledge (i.e., there is a “mismatch”). A caregiver provided an example of an individual interview where all of the questions were about that parent's experience with treatment. Even though the parent indicated early on in the interview that her children had never been treated for the condition, the interviewer continued to rigidly adhere to the protocol and ask questions about treatment. The “disconnect” between the questions and the parent's experience, and the lack of flexibility in the interview protocol (script) meant that s/he could not contribute meaningfully to the discussion and resulted in a “very frustrating experience” for her/him.

### Being the Only Patient/Patient Advocate in the Group Stakeholder Discussion Can be Intimidating

Participants reported that it can be difficult for a patient/patient advocate to meaningfully participate in a discussion when s/he is the only patient/patient advocate, and everyone else is a clinician/researcher with technical expertise. The patient/patient advocate often feels outnumbered which can be intimidating for her/him, particularly because the discussion is often highly scientific and technical, and the patient/patient advocate may not have been given the opportunity to read about the studies being discussed. Or if s/he was provided with the studies, they are difficult to understand because they are highly technical. Most of the clinicians/researchers are familiar with the studies being discussed, but the patients/patient advocates are not. As one participant stated,

- “Within this group I was the only patient, or parent of a patient, and I felt that could have been worked out. Maybe it couldn't have been, but even one more [patient] where it wouldn't have felt like me up against all these really smart people.”

In addition, being put in the position of having to represent all patients to a group of researchers and clinicians can be highly stressful and inhibit that person's willingness to participate. Some participants reported that patient advocates tend to be more familiar with scientific and medical concepts and with speaking in groups so they are often less intimidated in these group stakeholder discussions than patients. Ideally, they felt there should be at least one patient and one patient advocate in each group stakeholder discussion to ensure representation of both perspectives and also to lessen the likelihood that they will feel isolated or overwhelmed and think that “they do not have the right to voice their opinion.”

### Individual Interview Followed by Group Stakeholder Discussion Increases Patient KI Participation

While most of the participants participated in group stakeholder discussions with clinicians/researchers, two of them participated in individual interviews with EPC members. The two different formats were compared by the six participants during the focus group discussion, and overall, they liked the efficiency of the one-on-one format and the fact that an individual does not have to compete with others to be heard. In addition, they believed that relative to mixed group discussions, the one-on-one format allows patients to feel more comfortable about asking for clarification before answering and less intimidated about participating. However, when the participants were asked if only these individual meetings should occur, they consistently responded that there was great value for both the patients/patients advocates and the clinicians/researchers in being included in group stakeholder discussions and exchanging information. They felt it was particularly important for clinicians/researchers to hear the patient/patient advocate perspective. Therefore, they recommended that there be individual interviews of patients/patient advocates followed by a group stakeholder discussion with clinicians and researchers or a group stakeholder discussion with just patients/patient advocates followed by a mixed group discussion.

### Audio-Only Meetings are Not Ideal for Engaging Patient KIs

Lastly, the participants agreed that patients/patient advocates are more readily engaged when discussions are face-to-face rather than over the phone. Given that these group stakeholder discussions involve people from across the country, they understood that in person face-to-face meetings are not possible. When the UConn EPC team asked about the use of videoconferencing via something like WebEx, they all agreed this is a viable option that is preferable to audio only meetings but still inferior to face-to-face meetings.

## Followup to Group Stakeholder Discussions

### Majority of KIs Reported Not Reviewing the Draft Report

As with the actual group stakeholder discussion, engagement of the patients and patient advocates in the review of the draft report was quite variable across the EPCs. Some of the participants reported not being involved at all in the review of the report, and others were intimately involved. A participant who had a very positive experience indicated that s/he interacted with the EPC on a regular basis from the moment s/he was first contacted through to completion of the final report. After the group stakeholder discussion, s/he received an email that thanked her/him for her/his work and provided her/him with an outline of the next steps for the review. S/he was then sent a list of the parameters/questions that were going to be investigated in the draft report, which s/he was asked to comment on. And then when a draft report was available, s/he participated in a phone call to provide feedback on it. S/he felt very much engaged in the process and believed that her/his perspective was well-represented in the final report; s/he was “very satisfied” with the entire process, as indicated by her/his statement below:

- “What I thought they did well was they sent out the document to all of us to review, they welcomed feedback on it, they allowed things that we provided as input to be corrected if we didn't feel it was represented the way we wanted it. There were a couple of different ‘back and forths’ on that from a variety of people - it was a reply all, so nobody was excluded from that. And then the final copy was sent, and also [we were] told where it was going to be posted for final review. So I thought they did really well with communication on that at the end.”

Some of the KIs reported that they were not given the opportunity to review the draft report and had no idea what happened after the group stakeholder discussion. Another participant said that she did not hear anything for months after the group stakeholder discussion and then was sent the final report with no opportunity to provide feedback.

- “There wasn't follow-up. I think that an email of ‘we're moving into this stage’ or ‘we are submitting it’ or even a ‘hey, we got published, here's the link if you want to read it.’ I think that would have been helpful to follow up on what I contributed and how it helped and what it turned into.”

Some of the patients/patient advocates did not take the opportunity to read and comment on the draft report provided to them, because they felt it was mainly scientific and not their area of expertise. All of the participants agreed that if a patient/patient advocate did not feel engaged in the group stakeholder discussion, s/he is much less likely to read the draft version of the report when it is made available.

### Outreach to Patient KIs after Group Stakeholder Discussion can Facilitate Continued Involvement

Because participating in the group stakeholder discussion can be an intimidating experience for patients/patient advocates, it was suggested by one of the participants that the facilitator reach out to the patient/patient advocate after the call to determine if there is anything that s/he wants to add or if s/he has any questions that s/he did not feel comfortable asking on the phone. Participants indicated that this is often a much safer format for patients/patient advocates who were hesitant to talk in the group stakeholder discussion, who did not understand something and were worried about asking it, or who had time to think about what was discussed and have further comments or questions. They agreed that active follow-up by an EPC staff member can be very useful for engaging patients, caregivers, and patient advocates, and for collecting additional input.

### All KIs Indicated a Desire to Know What Happens After Evidence Report is Completed

All of the participants believed that there was great value in producing these evidence reports, but they had concerns about what happens to the final report after it is completed. They would like to know whether the recommendations that come out of the report “are being used in a clinical setting or changing the way physicians are treating or processing patients.” Is the information getting to the people who need it? As one participant stated, “I think that patients can be left feeling, ‘Well, that seemed important, but I'm not quite sure what happens next.’” There was consensus among the participants that it would be highly beneficial to distribute this information to patient advocates so that they can provide it to patients, families, and other key stakeholders. One of the participants reported that she actually presented the report that came out of her group stakeholder discussion at a national conference. Patient advocates are very motivated to disseminate the information in the report to their community: “It may be beneficial to have… a meeting where we could bring stakeholders together to discuss the findings and think about next steps and what needs to be done.”