# Conclusion

Based on the individual interviews and focus group discussion with the KI participants, they seemed open and honest and truly invested in AHRQ and the EPC program being as successful as possible. Key findings include the following:

- None of the participants regretted participating in a systematic review, and all indicated that they would be willing to do so again in the future.
- There was consensus among the participants that patients and patient advocates should be carefully selected for systematic reviews to ensure that they have the relevant experience and expertise.
- Participants agreed that easy-to-understand information should be provided to patients/patient advocates prior to the group stakeholder discussion so that there is no confusion about what their role is and the questions they should be prepared to answer.
- The person who facilitates the discussion needs to be an effective communicator who knows how to manage the group stakeholder discussion and ensure that everyone is given the opportunity to participate and feels valued and respected.
- Patients/patient advocates should be informed that there will be time allocated for them to share their perspective, the discussion will be highly technical at times, and although they are welcome to participate in the entire discussion, they can choose to withdraw from it when it becomes technical.
- There should be ongoing follow-up with the patient/patient advocates after the group stakeholder discussion to keep them abreast of what is happening with respect to the report and to maintain their involvement in the process.

It is important to keep in mind that while many of the recommendations from the patient advocates and caregivers who participated in this project may be worthwhile, they may not be feasible to implement or consistent with what AHRQ and the EPC program are trying to accomplish. However, they do represent a starting point in a discussion about best practices for selecting, engaging, and utilizing patients, caregivers, and patient advocates in systematic reviews. Also, the recommendations presented here along with the rest of the report need to be viewed in light of the aforementioned quality improvement project led by Amanda Borsky, DrPH, MPP, which directly solicited feedback from EPC discussion facilitators about how they engaged patients and patient advocates in group stakeholder discussions. It could be highly informative to compare the current patient/patient advocate report with the facilitator report and to use those findings to inform the development of consistent guidelines around patient/patient advocate engagement.

Lastly, we believe that creating some type of toolkit that specifies how to most effectively engage patients, caregivers, and patient advocates in systematic reviews could be extremely beneficial to EPCs and AHRQ. This toolkit could include the various recommendations enumerated in this report, as well as detailed information about how to be an effective facilitator. Patients, caretakers, and patient advocates are extremely valuable resources who can make significant and substantial contributions to systematic reviews if given the opportunity and support to do so.