# Background

The role of the Evidence-based Practice Centers (EPC) Program of the Agency for Healthcare Research and Quality (AHRQ) is to conduct comprehensive reviews of relevant scientific literature on various clinical and health services topics and to produce evidence reports that summarize the findings from these reviews. These reports can then be used to inform and develop clinical practice guidelines, research agendas, coverage decisions, quality measures, and educational materials and tools.

The public can participate in these reviews in a variety of ways, including proposing research topics in important areas. In addition, the public posting of Key Questions and draft evidence reports allows the public to provide insight and feedback at two key points of the systematic review process. And then providing the final reports and any translational products free of charge on its website (https://effectivehealthcare.ahrq.gov/) allows the general public to use the valuable information provided in these reports.

There are also times when members of the public are selected to participate on a panel or group to refine a project. Specifically, EPCs include patients, caregivers, and patient advocates in their systematic reviews (https://www.effectivehealthcare.ahrq.gov/ehc/assets/File/How-to-get-involved-EHC-Program-Guide-130515.pdf). The current project focuses on the inclusion of the patient perspective in Topic Refinement of a systematic review. A refined topic has three elements: (1) a clearly articulated population(s), intervention(s), comparator(s), outcome(s), timing, and setting(s) of interest, collectively referred to as the PICOTS, (2) Key Questions that are precise, detailed, and clearly focused, and (3) an analytic framework that represents the relationships between the elements of the PICOTS and the Key Questions (Figure 1). The Topic Refinement process includes a number of steps that begin with adapting preliminary materials from the initial topic nomination and development stage based on clinical expertise on the EPC team and a preliminary search of the literature, and ends with the refined topic and summary report being sent to the systematic review team for use in developing the systematic review protocol.

Figure 1 Systematic review process with focus on topic refinement

The first part of Figure 1 provides an overview of the systematic review process, which begins with “Topic Nomination and Development,” is followed by “Topic Refinement,” and then proceeds to “Conducting and Reporting on the Systematic Review.” Figure 1 then provides greater detail on the Topic Refinement portion of the process. Specifically, once a topic is selected, there is initial topic refinement, which comprises three steps: (1) defining or adapting PICOTS and the analytic framework, (2) adapting or creating key questions, and (3) identifying key issues for discussion with Key Informants. Next are the Key Informant interviews which consist of: (1) identifying relevant stakeholders, (2) scheduling and conducting interviews, and (3) integrating Key Informant feedback into the report. Following the interviews are synthesis and reporting which involves: (1) reviewing the revised document with topic experts, EPC, and AHRQ, and (2) developing a provisional summary report that transparently delineates the evolution of the topic over time and the proposed PICOTS, analytic framework, and key questions. Finally, there is public posting at the end of topic refinement.

EPCs use an inclusive and transparent process to refine a topic, so Key Informants (KIs) are selected for a panel that includes a broad range of health care stakeholders such as clinicians, prominent researchers in the area, and individuals who can represent the patient perspective, such as patients, caregivers, and patient advocates. After being sent preparatory information, the KIs have a group conference call with a facilitator from the EPC and a Task Order Officer from AHRQ. Alternatively, a member of the KI panel can have an individual call with only the EPC and AHRQ representative. The feedback from the KIs is used by the EPC to refine and revise the Topic Refinement Document.

Over the years, AHRQ and the EPCs have developed a methods guide (https://effectivehealthcare.ahrq.gov/ehc/products/60/318/CER-Methods-Guide-140109.pdf) which includes a chapter on Topic Refinement. There is additional guidance and training for facilitators and a checklist for putting together the KI panel agenda to improve the value of the KI calls.