# Appendix D KI Individual Interview and Focus Group Discussion Protocols

## Protocols for Patient Key Informant Interviews and Focus Group Discussion

### ONE-ON-ONE INTERVIEW PROTOCOL

#### INTRODUCE PROJECT AND GET CONSENT

- I want to thank you for agreeing to speak with us today. My name is Debbie Cornman, and I am a Clinical Psychologist at the University of Connecticut.
- Michael White from the University of Connecticut Evidence-based Practice Center is also on this call. [Allow Michael White to introduce himself.]
- I will be conducting the interview with you. Michael will mainly listen and take notes, but he will be given the opportunity to provide some information and ask some follow-up questions at various points.
- The recording has not yet started. I will turn it one once I have finished describing the project and you agree to continue.
- You have been invited to participate in today's interview because you previously provided input to at least one of the Evidence-based Practice Centers [specify the EPC] on one or more health topics [specify the health topic(s)].
- The University of Connecticut Evidence-based Practice Center is working with the Agency for Healthcare Research and Quality to better understand what that experience was like for you and what can be done to improve it.
- Since patients are the central focus of the health care system, to truly understand the most important aspects for the diagnosis and treatment of diseases, patients have to be at the table helping to shape research.
- We want to understand how can we best incorporate your and other [patients'/patient advocates'/parents'] feedback and experiences into the Agency for Healthcare Research and Quality systematic reviews.
- We want to understand your own experience with the AHRQ Evidence-based Practice Centers program, and your thoughts on what has and has not worked.
- You and other [patients/patient advocates/parents of patients] bring important expertise to the program, and we want to ensure that we are making the best use of that expertise and that [patients/patient advocates/parents of patients] are truly given the opportunity to contribute meaningfully to the program.
- Therefore, it is extremely important that you be as honest as possible with us about what you feel worked well and what did not, and how we can improve the process.
- There are no right or wrong answers to the questions that we will ask you today.
- Different Evidence-based Practice Centers have involved patients and patient advocates in different ways in systematic reviews, and we want to learn about the various approaches that Centers have used and the advantages and disadvantages of those approaches. So we are speaking individually with up to 9 patients, patient advocates, and parents of patients who have worked with Evidence-based Practice Centers around the country to learn about each person's experience participating in a systematic review.
- After we conduct individual interviews with each of the participants, we will bring all of you together to have a focus group discussion about what we learned during the interviews and talk in greater detail about suggestions for improvements to the AHRQ Evidence-based Practice Centers program.
- The day and time for that group discussion will be determined after all of the interviews have been completed.
- It is important for you to know that your interview today and the subsequent focus group discussion will be audio recorded so that we can review them at a later time. The audio recordings help ensure that we do not miss anything that you and others say.
- The audio recordings will be transcribed and then erased. All names will be removed from the transcripts so that no one can be identified.
- The only people who will have access to the transcripts are those conducting today's interview. The audio recordings (until they are erased) and the transcripts will be saved on a secure server at University of Connecticut.
- Everything that is said here today and in the focus group discussion will be kept confidential. All information from the individual interviews and the focus group discussion will be provided in summary form to AHRQ (Agency for Healthcare Research and Quality) and the Evidence-based Practice Centers (EPCs), and the summary will not indicate who said what. You and the other individuals who participate in this project will be given the opportunity to review and comment on the summary report prior to it being distributed.
- Please know that you are free to withdraw from the interview and the focus group discussion at any time without any consequences to you, including your medical care.
- You will see that we have provided you with a brief background questionnaire. We are collecting this information so that we can summarize the range of people who participate in this project. We ask that you NOT put your name on it so that we can maintain your confidentiality.
- Please know that you do not have to answer any questions on the questionnaire or during the interview or focus group discussion that make you feel uncomfortable.
- All of the information that I have presented to you is on the Information Sheet that we have provided to you. Please read it over, if you have not already done so.
- Do you have any questions about the interview or the focus group discussion or your participation in this project?
- Please take as long as you need before you make a decision about whether to participate.

#### CONDUCT INTERVIEW

We would like to understand your involvement in the Evidence-based Practice Centers program, from recruitment through completion. If you could briefly walk us through that experience, it would be very helpful. First, we will talk about the process and then about what worked and did not work with respect to that process.

1. Let's start with how you first got involved with [specify EPC project KI was involved in]. How did you first learn about the project? Who told you about it?
2. How clearly was the purpose of the project explained to you?
3. What was the reason that you agreed to participate in the discussion about [specify health topic focused on in KI's group stakeholder discussion]?
4. What happened after you agreed to participate?
5. What information, if any, were you given prior to the call to help you prepare?
6. How prepared did you feel for the discussion?
7. When the discussion occurred, was it a group discussion or were you the only person along with the discussion leader?
8. If it was a group discussion: What types of individuals participated in the group? Was it entirely [patients and patient advocates/parents of patients], or were there other people involved in the discussion as well, such as doctors and researchers?
9. What happened during the discussion? How much input did you have the opportunity to provide?
10. How comfortable did you feel talking openly and honestly during the discussion?
11. To what extent did you feel that your input was heard and mattered to those in the group?
12. What, if anything, surprised you about the discussion? Was there anything that happened during the discussion that you did not expect?
13. What, if anything, happened after the phone call discussion? Was there any follow-up?
  a. Were you notified when the draft report was released?
  b. Were you asked to review the draft report?
  c. Were you told how your feedback was used in the report?
14. Did you review the draft report, and if so, what was that process like?

[Allow Michael White to provide information on the purpose of EPC systematic reviews and group stakeholder discussions.]

Let's talk now about what worked well and what recommendations you have for changes to the Evidence-based Practice Centers program.

15 Thinking about when you were first contacted about the project, what recommendations, if any, do you have for providing [patients and patient advocates/parents of patients] with a clearer understanding of the purpose of a project?
16 What, if anything, could have helped you feel more prepared for the phone discussion?
  a. Was there particular information that you would have liked to have received prior to the call?
17 What recommendations, if any, do you have for making the phone call discussion more useful to the participants and to the program as a whole?
  a. What could the person leading the discussion have done differently to improve the discussion?
18 What suggestions, if any, do you have for follow-up after the phone discussion?
19 How could Evidence-Based Practice Centers make better use of [patients'/patient advocates'/parents'] expertise and experiences? What suggestions do you have for how to best incorporate [patients'/patient advocates'/parents'] feedback?
20 How representative do you think you are of [patients/parents of patients] with [specify health topic]? How similar do you think your experiences with [specify health topic] are to other [patients'/patient advocates'/parents'] experiences?
21 How likely would you be to participate in a similar type of project in the future? And why?

Ask Michael White if he has any other questions for the participant.

Ask the participant if s/he has any questions for the project team.

Thank you for participating in this interview. We truly do appreciate your honesty and your willingness to help us improve the process. Your feedback and the feedback from the other [patients/patient advocates/parents] being interviewed will be used to inform what we talk about in the focus group discussion. It is very important that we come out of the individual interviews and the focus group discussion with specific recommendations for the Evidence-based Practice Centers and AHRQ about how to make the systematic review process work as effectively and efficiently as possible. We hope you will join us and be an active participant on that call as well.

### FOCUS GROUP DISCUSSION PROTOCOL

#### EXPLAIN FORMAT AND EXPECTATIONS FOR GROUP DISCUSSION

Welcome to our group discussion. In case you do not remember, my name is Debbie Cornman, and Michael White is also on the call. We have spoken with each of you individually to get a better understanding of the particular Evidence-based Practice Center project in which you were involved, the process that you went through, and the strengths and weaknesses of that process. Based on those individual discussions, we understand that there was a range of approaches used by the various Evidence-based Practice Centers and that some approaches may have worked better than others. Today we will review what we learned about your experiences in systematic reviews and discuss the suggestions that all of you made for how to improve this program. Ideally, we would like to come up with specific recommendations that we can make to AHRQ and the Evidence-Based Practice Centers about what can be done to better involve patients, patient advocates, and caregivers in systematic reviews.

Your input is very important to us, so we would like to hear from all of you during the discussion today. We would appreciate it if you would give everyone a chance to speak. Also, because it is a bit more challenging to do this over the phone, it would be greatly appreciated if you would talk one at a time and try not to talk over one another.

Just as in the individual discussions, there are no right or wrong answers here. Our goal today is to come up with recommendations for how to better involve patients and patient advocates in systematic reviews that are conducted by Evidence-based Practice Centers. We do not expect everyone to agree with one another, but we do ask you to respect each other's experiences and opinions. We want to have as honest and frank a discussion as possible. There is a lot of wisdom in this group, and we can learn a lot from one another.

This is a confidential group, so whatever is talked about here must stay here. It is important that you understand that whatever we talk about today will not be revealed to anyone other than our project staff. Any information provided to others will be provided in summary form, and they will not be told who said what. It is important that all of you also maintain the confidentiality of this group.

Even though we are asking everyone here to maintain one another's confidentiality, we cannot guarantee that your name and comments made by you will not be revealed outside of this group by one or more of the other group members. Please keep this in mind when participating in this group discussion.

The group discussion will be audio recorded so that we can review it at a later time. The audio recording will be transcribed and then deleted. All names will be removed from the transcript so that you cannot be identified. All information from this group discussion will be provided in summary form, and it will not indicate who said what.

Please feel free not to answer any questions that make you feel uncomfortable. And you are free to leave the group discussion at any time for any reason.

Do you have any questions about the group discussion before we get started?

#### LEAD GROUP DISCUSSION

1. Prior to today's discussion, we sent out a summary of the key issues that came out of the individual interviews with the 6 of you. How many of you got a chance to read the summary, and what were your reactions to it?
2. Some of you indicated that you had a clear understanding of your role as a patient Key Informant and others of you were confused about it. What should Evidence-based Practice Centers do to ensure that patients and patient advocates fully understand their role before participating in a group stakeholder discussion?
  a. Some of the recommendations provided by you during the individual interviews include the following: [summary of recommendations from individual interviews]. Which of those recommendations do you agree with and why?
3. Let's talk now about preparation for a group stakeholder discussion. Some of you said that the Evidence-based Practice Center did a very good job of preparing you for the call, and others of you said that it was insufficient. What do you recommend as the best way for Evidence-based Practice Centers to prepare patients and patient advocates for a group stakeholder discussion?
  a. Some of the recommendations provided by you during the individual interviews include the following: [summary of recommendations from individual interviews]. Which of those recommendations do you agree with and why?
  b. What do patient/patient advocates need to be told ahead of time about the group stakeholder discussion so that they are able to fully participate in it? What type of information would be helpful to have prior to the call (e.g., goals of AHRQ and EPCs, background information on KIs participating in the group stakeholder discussion, Key Questions to be answered during the discussion, timeline of entire process)?
  c. In what form should information be provided (e.g., electronic, hard copy, verbal), and how much information is too much information?
4. What recommendations do you have for Evidence-based Practice Centers, and group facilitators in particular, to ensure that patient/patient advocates have the opportunity to provide feedback during the group stakeholder discussion? What is helpful and what is not helpful for engaging patients/patient advocates in the discussion? What could they do to help patients/patient advocates feel more comfortable about participating openly and honestly in the discussion?
  a. Some of the recommendations provided by you during the individual interviews include the following: [summary of recommendations from individual interviews]. Which of those recommendations do you agree with and why?
5. Two of you participated in a one-on-one interview with an EPC staff member. All but one of you participated in a group stakeholder discussion that included clinicians and researchers. Only one of you had another patient in your group. For the rest of you, you were the only patient/patient advocate in the group. What do you think is the most effective way to involve patients and patient advocates and get their honest input?
  a. What are the relative advantages and disadvantages of the different formats?
6. When asked about what type of follow-up occurred with you after the group stakeholder discussion, some of you said that there was ongoing follow-up by the EPC, and others of you said that you never heard from them again after the group discussion. How important is it to keep patients and patient advocates informed of progress on the project?
7. What recommendations do you have for follow-up after the group stakeholder discussion?
  a. Some of the recommendations provided by you during the individual interviews about follow-up include the following: [summary of recommendations from individual interviews]. Which of those recommendations do you agree with and why?
  b. What do you think about the following forms of follow-up: (1) providing patients with a summary of the discussion so that they can assess whether their comments were accurately represented by the discussion leader, (2) notifying patients when the draft report has been completed so that they can review it, if they so choose?
8. When we asked you about whether you would agree to participate in a similar project in the future, all of you said that you would even though some of you were frustrated with how the process was conducted. What could the Evidence-based Practice Centers or AHRQ do to make it more likely that patients and patient advocates would participate in EPC systematic reviews?
9. Looking at the entire systematic review process from beginning to end, what additional recommendations do you have for the Evidence-based Practice Centers and AHRQ to make the process more effective and user-friendly, particularly for patients and patient advocates?

Ask the participants if they have any questions for the UConn EPC project team or anything else they would like to share.

Thank you so much for participating in this project. We will be compiling all of the feedback that you provided during the individual interviews and the focus group discussion into a summary report that will be distributed to the Evidence-based Practice Centers and AHRQ so that they can better understand what they are doing well and what they need to improve upon. Before sending it to them, however, we would like to give you the opportunity to review the report and provide feedback on it.

We want to thank you for being so generous with your time and effort. The information that you provided to us is extremely important and valuable, and I have no doubt that it will be used to make the Evidence-based Practice Centers program as effective and useful as possible.