# Appendix C Key Informant Background Questionnaire

BACKGROUND QUESTIONNAIRE FOR EPC PATIENT ENGAGEMENT PROJECT