# Appendix B Information Sheet

[image]

Project Leaders: Deborah H. Cornman, PhD and C. Michael White, PharmD, FCP, FCCP

Project Title: Discerning the Perception and Impact of Patients Involved in Evidence-based Practice Center Key Informant Interviews

Sponsor: Agency for Healthcare Research and Quality (AHRQ)

## Introduction

You are invited to participate in a project that is examining the experience of patients who have served as Key Informants for systematic reviews conducted by the Agency for Healthcare Research and Quality's Evidence-based Practice Center (EPC) program. The purpose of this quality improvement project is to learn from you and other patients who have served as Key Informants how you were originally identified, prepped for the group stakeholder discussion, and treated during that discussion, and to get specific recommendations from you on how best to increase patient involvement and improve the experience of patients in these systematic reviews.

## What are the project procedures? What will I be asked to do?

If you choose to be in the project, you will be asked to participate in an individual interview followed by a focus group discussion with up to 8 other patients, caretakers, and patient advocates who have previously participated in systematic reviews. You will also be asked to complete a brief one-page background questionnaire, with questions about your age, gender, race, ethnicity, and the number and location of EPC projects you have been involved in. The interview and focus group discussion will focus on how prepared you felt for the group stakeholder discussion, what the experience was like participating in a systematic review, what type of follow-up there was, and any recommendations that you have for improving the process.

Both the individual interview and focus group discussion will be conducted over the phone by trained clinical psychologist Debbie Cornman. Project Leader Michael White and a member of the AHRQ will also be on the call and may ask some follow-up questions. These conversations will be audio recorded and transcribed. It is expected that the interview will take no more than 60 minutes, and the focus group discussion (conducted at a later date) will take up to 1½ hours. Any personally identifying information will be removed from the transcripts before they are analyzed. The audio recordings will be deleted after they have been transcribed.

## What are the risks or inconveniences of this project?

Your involvement in this project does not require you to have procedures or treatments, and you are not being asked about any diseases or disorders that you have. Since you are only being asked about your experience as a Key Informant in a systematic review, the risks to you are minimal.

There is a slight risk that your participation in this project may become known to others outside of this project if someone in the focus group discussion reveals your identity, but that is unlikely because the group discussion is being conducted over the phone, and we are asking participants not to identify themselves by name during the discussion. And the researchers themselves are required to keep your identity and the information that you provide confidential.

Lastly, there is the possible inconvenience of having to spend a combined total of 2½ hours of your time on the interview and focus group discussion.

## What are the benefits of this project?

There is no potential direct benefit to you unless you participate in another systematic review and group stakeholder discussion. The feedback that you and the other participants provide will be used to better understand how to effectively engage patient stakeholders in the Evidence-based Practice Center (EPC) systematic review process. The feedback provided during the interviews and focus group discussion will be given in summary form to both the Agency for Healthcare Research and Quality (AHRQ) and the EPCs, who will use it to decide what changes need to be made to improve patients' involvement in systematic reviews. Since the EPCs conduct projects on an ongoing basis, you might be asked to participate on another systematic review in the future, and if that occurs, you could benefit directly from any improvements that are made to the EPC program.

## Will I receive payment for participation?

You will receive a $40 gift card after you complete the focus group discussion.

## How will my personal information be protected?

Numerous steps will be taken to protect your personal information:

1. Your name and contact information will be stored on a secure server at University of Connecticut and not shared with anyone outside of the project team. This information will be stored in a separate file from the responses that you provide during the project.
2. All audio recordings, transcripts, and background questionnaire responses will be stored on a secure server at University of Connecticut. Access to this information will be limited to project staff.
3. We will not use your name during the interview or the focus group discussion, and we will not reveal what you say to anyone outside of the project team, including the EPCs. All responses will be provided in summary form and will not indicate who said what.
4. Any personal information that is revealed by you during the interview or focus group discussion will be removed from the transcript prior to analysis. The audio recordings will be deleted once the transcripts have been completed.
5. All group participants will be asked to maintain the confidentiality of the group members.
6. All group participants will be given the opportunity to review and comment on the draft summary report prior to it being distributed to the AHRQ and the EPCs.

We will do our best to protect the confidentiality of the information we gather from you, but we cannot guarantee 100% confidentiality.

## Can I stop being in the project, and what are my rights?

Participation in this project is voluntary, and you do not have to be a part of this project if you do not want to be. If you agree to be in the project, but later change your mind, you may drop out at any time. There are no penalties or consequences of any kind if you decide that you do not want to participate; it will not affect your medical care, your relationships with your health care staff, or your opportunity to participate again in an EPC systematic review. In addition, you are free to skip any questions that you do not wish to answer, for any reason.

## Whom do I contact if I have questions about the project?

Take as long as you like before you make a decision about whether to participate. We will be happy to answer any questions you have about this project. If you have further questions or concerns about this project, you may contact Debbie Cornman at 860-208-3035 or at deborah.cornman@uconn.edu.