# Appendix A Email and Recruitment Document

From: Borsky, Amanda (AHRQ/CEPI)

Subject: Help Requested - Recommend 2 patients from prior KIs

Date: Thursday, September 08, 2016 8:02:19 AM

Attachments: [underlined: Attachment Recruitment.docx]

_________________________________________________________________________________________

Good morning EPC PMs:

Attached please find a one-page summary of the patient engagement methods project (attachment 1) the University of Connecticut EPC will be conducting over the Fall of 2016. Like we discussed at the Spring 2016 Director's Meeting we are hoping to identify patient-perceived best practices for patient stakeholder engagement that EPCs can use during their systematic reviews. But, to make the project a success, we need to find 9 patients from 9 different EPCs who would be willing to participate.

Would you please identify two patients that you have used in the past and provide us with the project they participated in, their contact information, and how well you felt they were engaged? If you could identify one person who you perceived had a positive experience and one who had a less than perfect experience, that would be most helpful to us in our work but we understand that you might be able to remember or assess their experience. More recent participants (those over the past 3 years) will have fewer issues with recall and be preferred. We will provide patients with a $40 gift card incentive for fully participating.

We would like to be able to start contacting patients as soon as possible (by no later than September 30, 2016) so it would be very helpful if you could make contact over the next few weeks. We will follow-up with them and answer any additional questions they might have if they are interested in hearing more.

If you have any questions, please don't hesitate to contact Charles.White@uconn.edu or Deborah.Cornman@uconn.edu. Please also send your suggestions directly to Mike and Deborah. Thank you!

- Best regards,
- Amanda

- Amanda Borsky, DrPH, MPP
- Dissemination and Implementation Advisor
- U.S. Preventive Services Task Force and Evidence-based Practice Center Programs
- Center for Evidence and Practice Improvement
- U.S. Department of Health and Human Services
- Agency for Healthcare Research and Quality
- 5600 Fishers Lane, Mailstop 06E53A, Room 06E61C
- Rockville, Maryland 20857
- Phone: 301-427-1602
- Fax: 301-427-1520
- Email: Amanda.borsky@ahrq.hhs.gov

Attachment 1:

Discerning the Perception and Impact of Patients Involved in Evidence-based Practice Center Key Informant Interviews

University of Connecticut Evidence-based Practice Center, Storrs, CT

## BACKGROUND

In April 2016, AHRQ sought to discern the ways in which patients or caregivers were being engaged and held focus groups with EPC personnel who run stakeholder discussions. While the discussion was robust and elucidated some successful practices and barriers, it was felt that directly querying the patients who had supported our projects in the past would be a vital piece to establishing best practices.

## SPECIFIC AIMS

- Discern the general level of satisfaction that patients had as a result of participating.
- Elucidate how patients were invited to participate, what information was provided to them, and how their feedback was incorporated.
- Compare and contrast the responses between the patients and those in the focus group of EPC personnel conducted previously.

## METHODS

Patients (n=9) involved as stakeholders in EPC projects are eligible if they are US citizens ≥ 18 years and have the ability to speak and understand English. EPCs will contact patients that they used as stakeholders in the past, and if the patients are amenable to participating or hearing more about the quality improvement projects, they will be contacted by the quality improvement team for this project.

In individual interviews, we will focus on the individual's experiences in the program, the process that was followed by the EPC when s/he was identified, educated, and utilized in the project and her/his feelings about that.

In focus group interviews, we will assess differences in approach and sentiment as to how these stakeholders were engaged and ask for thoughts on comparative strengths and weaknesses of the approaches. They will also be asked to identify approaches that have not been used in the EPC program but have been used elsewhere. We feel that the focus group as an extension of the personal interviews will allow us to gain insight from these stakeholders in two complementary approaches that replicate the ways in which patients are currently used in the EPC program (i.e., individually engaged without being a part of the larger group or in a large group with all stakeholders being present).

Data will be audio recorded and then transcribed, reviewed, analyzed, and summarized by the investigative team. Data will be assessed individually and then will be compared and contrasted to the responses the EPC personnel provided in their aforementioned focus group on patient engagement.

## TIMELINE

The quality improvement investigative team will present information at the Spring EPC Director's Meeting and ask for EPCs to start identifying patients or caregivers that would be amenable to participating and contacting them. We will follow-up with an email explaining the project and the need for EPC support in identifying participants. Individual and focus group meetings will be conducted over the Fall with results available for the Spring EPC Director's Meeting.