# Results

## Literature Search

Overall we found 24 articles describing—in more or less detail—the benefits, challenges, or approaches to measuring and evaluating the impact of stakeholder engagement. The majority focused on stakeholder engagement in primary research, and only a few articles were specific to systematic reviews. In general, the articles described developing perspectives, recent experiences, and tools or best practices for conducting stakeholder engagement. See Appendix B Table B-1 to Table B-5 for a full listing of the relevant information extracted from each article.

Although the literature on stakeholder engagement in primary research touched on a wide range of benefits, most studies relied on observations and inferences, with very few directly measuring the impact of stakeholder engagement. Benefits cited included identifying and prioritizing topics for research; providing pragmatic feedback on the research protocol; aiding in recruitment of research participants; helping the researchers understand the research subject's perspective; ensuring that findings are interpreted with the end user in mind and that final products are readable and accessible; and facilitating wider dissemination and uptake of research findings. There was almost no discussion of measurement or evaluation of the impact of stakeholder engagement.

Of the handful of the studies we reviewed that reported on the effect of stakeholder engagement on the quality and impact of systematic reviews, the majority were specific to the UK. Several general benefits were articulated, including refining the scope and improving the quality of the review, suggesting and locating relevant literature, interpreting the review findings and putting them into perspective, improving the readability and clarity of the report, and contributing to wider dissemination and utilization of the findings. 8-12 However, as in the literature on stakeholder engagement in primary research, there was no effort to explicitly measure the impact of stakeholder engagement and/or evaluate whether, how, and through what means these suggested benefits were achieved.

The need for additional time and resources was cited as one of the primary challenges of engaging stakeholders in both primary research and systematic reviews.8, 12, 13 Moreover, concerns about the representativeness of stakeholder perspectives, the ability of stakeholders to participate consistently throughout the review process,8 and the potential of merely tokenistic involvement were also raised.13

Although the studies cited above articulate a general sense of the benefits and challenges of stakeholder engagement, the literature is silent on the topic of how to measure the impact of their involvement. Indeed, there has been little effort to explicitly evaluate impact or develop quality standards for stakeholder engagement in systematic reviews or even in health research more broadly. In a recent systematic review of the impact of patient and public involvement in health and social research, Brett, et al. concluded that the impact of public and stakeholder engagement is weak and poorly reported.14 Specific to systematic reviews, Boote, et al. suggested that we need to find out more about what works best, for whom and in what circumstances.8 Both authors (and a number of other articles reviewed for this paper), highlighted the need to evaluate the impact of stakeholder involvement on the systematic review process, to make explicit the contribution of stakeholders at different stages of the review, and to develop quality standards.8, 14 In short, although the existing literature supports the EHC program's belief that stakeholder involvement provides important concrete benefits to systematic reviews (see summary in Table 1, for example), the discussions of specific benefits and challenges are broad and lack the refinement necessary to design a set of measures for evaluating the impact of stakeholder engagement on the systematic review process.

Table 1 Literature search: Potential benefits and challenges of engaging stakeholders in systematic reviews

Benefits
- Refine scope
- Improve quality
- Suggest and locate relevant literature
- Interpret findings/put findings in perspective
- Improve readability and clarity of report
- Increase dissemination and utilization of findings
Challenges
- Additional time and resources
- Selection of stakeholders/achieve representativeness
- Reliability/consistency in participation
- Maintain confidentiality
- Manage and support stakeholders
- Overcome tokenism

## Key Informant Interviews

Of the 60 KIs we invited, 34 agreed to participate –15 systematic reviewers who engage stakeholders in their work, 10 programmatic officials who commission systematic reviews, and 9 stakeholders who have been involved in the systematic review or research process. In all, we conducted twelve 60 to 90 minute discussion sessions with between one and four participants each. All policymakers also represented another perspective, so their input could not be called out separately. Indeed, it was not uncommon for stakeholders to represent more than one perspective. Overarching themes from our KI interviews were organized according to the three guiding questions of this white paper: (1) What are the potential or expected benefits of involving stakeholders in systematic reviews? (2) What are the challenges of involving stakeholders in systematic reviews? (3) How can we measure the impact of stakeholder engagement in systematic reviews?

### What Are the Primary Expected Benefits of Involving Stakeholders in Systematic Reviews?

Overall, the expected benefits described by KIs clustered into six overarching domains: (a) establishing credibility, (b) anticipating controversy, (c) ensuring transparency and accountability, (d) improving relevance, (e) enhancing quality, and (f) increasing dissemination and uptake of systematic review findings. Appendix D provides excerpts from KI interviews regarding the expected benefits of engaging stakeholder in reviews.

#### Establishing Credibility

Systematic reviewers and programmatic officials in particular commented on the importance of engaging stakeholders from the beginning of the systematic review process in order to establish credibility and gain stakeholder buy-in. When stakeholders are engaged from the beginning, they are more likely to understand the process and feel that their insights are incorporated into the design and conduct of the review. The very act of engagement helps to establish the credibility of both the systematic review process and the final report. KIs who had been engaged in a review as a stakeholder reported that it gave them a sense of investment in the process and findings, as opposed to feeling that the results were simply “announced” to them at the end.

#### Anticipating Controversy

Several KIs explained that a key benefit of engaging stakeholders is the ability to anticipate controversies and opposing views that could potentially derail a report's relevance. Systematic reviewers and programmatic officials in particular underscored the imperative of understanding the context and history of a given topic, including areas of scientific uncertainty or debate and politically charged or “hot button” issues from a consumer or advocacy perspective. Moreover, they described instances when stakeholders were able to uncover “blind spots” including issues of current debate or concern that impacted what questions were asked or how the report's findings were communicated. Although it isn't always possible to completely prevent controversy, especially when reviewing important topics, there was a general consensus that having a comprehensive understanding of the potential issues in advance enabled systematic reviewers to be more prepared to respond to criticism or controversy should it arise.

#### Ensuring Transparency and Accountability

KIs described the benefit of engaging stakeholders in the review process as key to ensuring transparency and accountability, particularly in situations where systematic reviews directly determine policy. KIs from the stakeholder and policy/programmatic perspective suggested that engaging a broader community in the process is a democratic right. One stakeholder argued that engaging the public in making decisions about the direction of a systematic review and ensuring that the process is geared towards questions and issues that are relevant to them is a moral imperative. Systematic reviewers and program officials both noted that mandates to engage stakeholders are important aspects of displaying accountability, transparency, and ongoing support for systematic reviews.

#### Improving Relevance

KIs from all perspectives suggested that a primary motivation for engaging stakeholders is the belief that engaging the end users – patients, clinicians, policymakers, or guideline developers – is necessary to produce reports that are timely, relevant and address real-world dilemmas. There was general agreement that engaging those who would use the evidence was the best way to ensure that a systematic review addresses the right questions, includes the right outcomes, and that the review team does not miss a critical perspective. KIs repeatedly emphasized that stakeholders bring an understanding of the context that comes from having in-depth professional or personal experience with a topic and that without this input systematic reviews could miss the target and end up gathering dust on shelves rather than changing practice.

#### Enhancing Quality

In addition to improving relevance, systematic reviewers and program officials identified a number of specific areas where stakeholder input improved the scientific quality of the final report, including: framing the review and defining the key questions; helping the team to refine the scope of the review; and establishing appropriate parameters for the population, intervention, comparator, outcome, timing and settings (PICOTS) considered. Systematic reviewers credited stakeholder input with identifying nuances that were integral in helping to clearly define the PICOTS considered in a given review. Moreover, clinical experts were identified as instrumental in providing valuable context that may not be readily apparent from the published literature, including identifying tests and procedures that are obsolete, or highlighting dosing and side effect profiles of different classes of medications that may influence study findings.

The majority opinion was that engaging patients in the other technical aspects of the report, such as gathering, qualifying, analyzing, and reporting the findings, was not as valuable, unless they had research or clinical background and training. However, a number of systematic reviewers suggested that engaging clinical experts during the conduct of the review could add substantial value, ensuring that they hadn't missed any critical or high-impact studies, further refining inclusion and exclusion criteria, and helping the team to “read between the lines” of the published studies and highlight issues that might not be readily apparent to those not so familiar with the clinical context. The value of contacting industry stakeholders to identify ongoing studies relevant to the review was also noted.

#### Increasing Dissemination and Uptake of Systematic Review Findings

All of our discussions touched in some fashion on the idea of engaging stakeholders as a route to improving the dissemination and uptake of systematic review findings. KIs from all perspectives agreed with the principle that involving stakeholders meaningfully in the process should, at least in theory, increase the likelihood that systematic reviews address the right questions; are relevant to the real-life decisions faced by patients, clinicians, and policymakers; and that the findings are actually used to guide and inform real-life medical decisions. Moreover, KIs expressed the hope that by involving stakeholders in the conduct of systematic reviews, they are likely to become advocates for the results, thereby facilitating more widespread dissemination and uptake of the final product. However, despite agreeing on the principle that engaging stakeholders can facilitate dissemination and uptake of reports, there was also consensus that we still have more work to do as a field to improve the dissemination and uptake of evidence.

### What are the Challenges of Involving Stakeholders in Systematic Reviews?

Part of understanding the value of stakeholder engagement is recognizing the challenges and tradeoffs that are involved. KIs identified the following overarching challenges to involving stakeholders in systematic reviews: (a) time, (b) training and resources (for stakeholders as well as researchers who would engage them), (c) finding the right people, (d) balancing multiple often competing inputs, and (e) understanding when to engage specific types of stakeholders. Of the challenges, two are tradeoffs (time and resources), which have to be balanced against the benefits generated by stakeholder engagement or else minimized. The others are potential problems that, unless addressed by the engagement process, can prevent the benefits from being realized. Appendix D provides excerpts from the KI interviews to illustrate these themes.

#### Time

First and foremost, KIs from all perspectives agreed that engaging stakeholders requires a significant investment of time, especially if it is to be done well. Systematic reviewers repeatedly emphasized that engaging stakeholders in the systematic review process lengthens the project timeline, especially if stakeholders are engaged at more than one time point. Given how rapidly new research becomes available, this can be a significant problem for systematic reviews. There was disagreement as to whether the extra time involved resulted in an improved product, with some arguing that the time spent engaging stakeholders was at least partly recouped by avoiding missteps, and others arguing that getting the results out to stakeholders earlier was more important than engaging them in the systematic review process. This investment of time was cited as an issue for stakeholders as well. Meaningful involvement in a systematic review requires a great deal of time and energy, and by definition stakeholders usually have other professional or caregiving responsibilities.

#### Training and Resources

KIs also agreed that engaging stakeholders requires a significant investment of resources, and that lack of the appropriate training and resources can limit the benefits of the stakeholder engagement. Many investigators are unfamiliar with how to best utilize and engage stakeholders and lack the skills required for successful management of such a process. Moreover, stakeholders who do not have a clinical or research background may require additional training and ongoing support in order to make a meaningful contribution to the process. KIs from all perspectives, but especially systematic reviewers and those who had served as stakeholders, suggested that ensuring that both sides have the necessary background and training, and sufficient resources to support their role, would go a long way toward increasing the overall benefit of stakeholder engagement in systematic reviews. The training time and additional resource requirements were seen as very real and requiring acknowledgement by those commissioning and supporting stakeholder engagements in systematic reviews; these requirements also underscore the need for better specification in the activities of stakeholder engagement.

#### Finding the Right People

Identifying and inviting stakeholders to participate in the review process is not an exact science and figuring out whom to engage can be challenging. Moreover, because Federal regulations limit the number of stakeholders who can be engaged in a given review, the choice of who to engage carries a great deal of weight. Getting it wrong can limit or negate the value of the engagement. During one discussion among systematic reviewers, there was agreement that in many instances the benefit of engagement is highly correlated with which types of stakeholders are engaged and/or the make-up of the stakeholder group.

KIs who had been involved as stakeholders and systematic reviewers alike noted that not all stakeholders have the same level of commitment and/or ability to contribute significantly to the systematic review process. Engaging those with high commitment runs the risk of engaging those with the most conflicts of interest. Moreover, as highlighted above, stakeholders who are not intimately familiar with the scientific review process may need substantial background and training in order to make valuable contributions.

Both stakeholders and systematic reviewers also emphasized that beyond their clinical expertise or personal experience with the topic, less tangible (or readily apparent) individual characteristics often play a large role in shaping the value and impact of stakeholder engagement, including: personality traits, their level of social influence among their peers, their level of personal motivation and willingness to engage, comfort with sharing their opinions amongst a room full of “experts,” and comfort with group processes. Some even suggested developing a database of “good stakeholder” contacts so that those that are a proven asset to this type of work can be accessed for future work.

#### Balancing Multiple Inputs

Another challenge is defining the relative value of different stakeholders input. Only a limited number of stakeholders are engaged per review and it can be a challenge to determine whether a particular stakeholder is an outlier or has a personal or political agenda. As one systematic reviewer emphasized, not all stakeholder input is equal and it is often difficult to assess which points to incorporate. It is a delicate balance to make stakeholders feel that their insights are valued, while at the same time being mindful that not all ideas can be incorporated into the review as there are scientific as well as resource issues to also consider. Some systematic reviewers expressed concern about expectations associated with being able to respond to all opinions expressed through stakeholder engagement. On the other hand, KIs who had served as stakeholders reported feeling pressure to come up with new or interesting insights or contributions or raise issues that the systematic review team had not addressed. Stakeholders also reported feeling intimidated by the process or under pressure to serve as the representative voice for a large population of people.

#### Understanding How To Match the Right Type of Stakeholder to the Right Time in the Systematic Review Process

An overarching theme from many of the systematic reviewers was the concern that mandates for more extensive stakeholder engagement in systematic reviews seem to suggest that “more is better,” but there has been less attention to understanding when in the process it is most useful to engage a particular type of stakeholder. There was concern that we lump all stakeholders together into a homogenous group, without recognizing the different contributions that different types of stakeholders can bring at each point in the review. This increases the time and resources needed and risks frustrating or burning out the participants.

### How Can We Measure the Impact of Stakeholder Engagement?

Because the practice of engaging stakeholders in systematic reviews is still relatively young, there has been almost no formal assessment of the impact of stakeholder engagement to date. The limited number of studies identified in our literature search focused primarily on measures of the engagement process (i.e., whether the process was transparent and stakeholders were engaged as partners), as opposed to the actual impact of the engagement on the design, conduct, or dissemination of the systematic review. With the exception of a small minority of KIs who felt that efforts at measurement in this area were futile and not the best use of scarce resources, there was general agreement that there is a need to further define what discrete benefits and impacts are expected from stakeholder engagement and to develop methods to measure and evaluate them.

Regardless of their perspective on the utility of this endeavor, we asked KIs to brainstorm and help think through strategies for evaluating the effectiveness of stakeholder engagement (see Appendix D for excerpts from KI interviews). Overall, there was consensus that it is important to build a better understanding of what we are trying to achieve and who and when we should engage to best achieve this goal. The most frequently cited method to capture the benefit and impact of stakeholder engagement was to evaluate the quality and validity of the review and how widely the review is used. For example, KIs suggested that tracking how a review is used to guide policy decisions or guideline development may be an important indicator of impact. Another suggestion was to evaluate whether a report resulted in the generation of new research or helped to spur the release of targeted requests for proposals. Moving beyond a simple assessment of the number of peer-reviewed articles and citations, and devising a way to assess the degree of dissemination and uptake in clinical practice by monitoring the number of page views or Internet downloads for a given report was also cited as another potential route for measuring impact.

Other KIs proposed very pragmatic measures of the effectiveness of stakeholder engagement, such as tracking the changes in key questions, inclusion and exclusion criteria, or other elements of the review. Consistent with findings from the published literature, efforts could also be made to survey or conduct informal briefings with the stakeholders who were engaged in the review to assess their perspective on the effectiveness of the process and the overall utility of the final report. Surveys to assess whether stakeholders involved in framing key questions could see any of their ideas incorporated could potentially measure this, although lack of incorporation could reflect competing input and scientific limitations as much as “failure” of engagement. This example illustrates the challenge of designing appropriate measures for engagement. One KI suggested that achieving “saturation” of new ideas before discontinuing stakeholder engagement at the research plan phase could be predictive of more useful reports. If this theory holds promise, it could be relatively easily evaluated qualitatively using recordings or transcripts of stakeholder engagement activities.

Empiric evaluation was also identified as a possible route to measuring effectiveness. AHRQ could assign a review to two different EPCs and ask one to engage stakeholders in the process, but not the other, and compare the overall quality of the reviews and perhaps evaluate their usefulness from the stakeholder perspective. A number of systematic reviewers mentioned the possibility of looking at this question retrospectively by comparing the quality and usefulness of past reports with varying degrees of stakeholder engagement. Another suggestion was to survey matched stakeholders who were or were not engaged regarding their perceptions of the utility of a systematic review, whether they actually used the review, and needed improvements. Alternatively, stakeholder input could be deliberately phased in to allow measurement of changes across a range of topics. One challenge in this approach would be in determining when change was just change and when it was “better.”