# References

1 Curtis P, Slaughter-Mason S, Thielke A, et al. PCORI Expert Interviews Project: Final Report Center for Evidence-based Policy. Oregon Health & Science University. Portland, OR. 2012. http://pcori.org/assets/pdfs/Expert%20Interviews%20Part%201.pdf.
2 Guise JM, O'Haire C, McPheeters M, et al. A practice-based tool for engaging stakeholders in future research: a synthesis of current practices. J Clin Epidemiol. Jun. 2013;66(6):666-74. [pmid: 23497857].
3 (PCORI) MCotP-CORI. Methodological standards and patient-centeredness in comparative effectiveness research: The PCORI perspective. JAMA. 2012;307(15):1636-40. [pmid: 22511692].
4 Institute of Medicine. Initial Priorities for Comparative Effectiveness Research. Washington. The Institute. 2009.
5 AHRQ. AHRQ Effective Health Care Program: Stakeholder Guide. 11-EHC069-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011. http://www.ahrq.gov/research/findings/evidence-based-reports/stakeholderguide/stakeholdr.pdf. January 2013.
6 Helfand M, Balshem H. Principles in developing and applying guidance. Methods Reference Guide for Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
7 Brett J, Staniszewska S, Mockford C, et al. The PIRICOM Study: A systematic review of the conceptualisation, measurement, impact and outcomes of patients and public involvement in health and social care research. UK Clinical Research Collaboration. 2010. http://www.google.com/url?sa=t&rct=j&q=piricom%20study%20a%20systematic%20review%20of%20the%20conceptualisation&source=web&cd=1&ved=0CDQQFjAA&url=http%3A%2F%2Fwww.ukcrc.org%2Findex.aspx%3Fo%3D3234&ei=9PfUULL2A6X02wWSw4D4AQ&usg=AFQjCNGeFVKDQJTKheuYKHuPuS8c4UlpPw&bvm=bv.1355534169,d.b2I. July 2013.
8 Boote J, Baird W, Sutton A. Involving the public in systematic reviews: a narrative review of organisational approaches and eight case examples. J Comp Eff Res. 2012;1(5):409-20. [pmid: 24236418].
9 Keown K, Van Eerd D, Irvin E. Stakeholder engagement opportunities in systematic reviews: Knowledge transfer for policy and practice. J Contin Educ Health Prof. 2008;28(2):67-72. [pmid: 18521874].
10 Serrano-Aguilar P, Trujillo-Martin MM, Ramos-Goni JM, et al. Patient involvement in health research: a contribution to a systematic review on the effectiveness of treatments for degenerative ataxias. Soc Sci Med. 2009;69(6):920-5. [pmid: 19647357].
11 Involve, National Institute for Health Research. Public involvement in systematic reviews: Supplement to the briefing notes for researchers. INVOLVE. Eastleigh, UK. 2012. http://www.invo.org.uk/wp-content/uploads/2012/10/INVOLVEPublicInvolvementSystematicReviews2012.pdf. January 2013.
12 Hailey D. Consumer involvement in health technology assessment (Structured abstract). Health Technology Assessment Database. Alberta Heritage Foundation for Medical Research. 2005.
13 Gauvin FP, Abelson J, Giacomini M, et al. “It all depends”: Conceptualizing public involvement in the context of health technology assessment agencies. Soc Sci Med. 2010;70(10):1518-26. [pmid: 20207061].
14 Brett J, Staniszewska S, Mockford C, et al. Mapping the impact of patient and public involvement on health and social care research: a systematic review. Health Expect. 2012. Jul. 19. Epub ahead of print. [pmid: 22809132].