# Methods

## Literature Search

As a first step, we searched the published and gray literature to identify studies that address the benefits, challenges, and/or measurement of stakeholder engagement. The specific aims of this review were to: (1) understand the overall state of the field and whether there were existing efforts to explicitly define or evaluate the impact of stakeholder engagement in primary research or systematic reviews, and (2) better inform and focus the KI interviews.

We searched a range of databases, including Ovid MEDLINE, EBM Reviews (Cochrane Database of systematic Reviews, Cochrane Methodology Register, Database of Abstracts of Reviews of Effects, Health Technology Assessment) and Scopus (see Appendix A for the complete search strategy). A gray literature search identified relevant guidance issued by internationally recognized organizations, including the Cochrane Collaboration, National Institutes for Health and Clinical Excellence (NICE), Campbell Collaboration, U.S. Preventive Services Task Force, and others. Additional citations were identified both via research team members and by pearling of relevant article bibliographies. The final search strategy is listed in Appendix A.

Abstracts and full text articles were reviewed for relevance by three investigators. We included articles that described the benefits, challenges, and/or measurement of stakeholder engagement in systematic reviews or health research more generally, including primary research and health technology assessment. We excluded articles that were published prior to 2005,^a^ those that primarily focused on how to engage stakeholders (instead of why or when), and those that were not relevant to health research or systematic reviews. Of the 299 abstracts and 80 full-text articles reviewed, 24 addressed in some fashion the benefits, challenges, measurement or evaluation of stakeholder engagement. Relevant information was extracted from each of these 24 articles (see Appendix B).

a The AHRQ Effective Healthcare Program was established in 2005.

## Key Informant Interviews

To ensure a comprehensive understanding of the benefits and challenges of stakeholder engagement within a systematic review (or EPC) context and identify any existing formal or informal efforts to measure or evaluate the impact of engagement, we conducted a series of interviews with those who know the most about this process: systematic reviewers who engage stakeholders in their work, programmatic officials who commission systematic reviews, policy makers who use systematic reviews, and stakeholders who have been involved in the systematic review or research process.

Potential KIs from each of the above groups were identified by members of our working group and invited to take part in a 90-minute individual or group interview between April 2 and April 29, 2013. We invited 60 KIs from across the 4 perspectives highlighted above. One investigator facilitated all of the interviews. Each KI completed an “EPC Conflict of Interest Disclosure Form” prior to being interviewed and no conflicts were reported that prevented participation for any individual. We asked all KIs for their permission to audio record and transcribe the discussions and acknowledge their participation in our final White Paper, also assuring them that no individually identifiable information would be included in our final report.

To guide the interviews, we developed a set of semi-structured interview questions designed to elicit a multi-faceted understanding of the value of engaging stakeholders in systematic reviews, including the expected benefits and challenges (see Appendix C). Our goal was not to test a specific hypothesis, but rather to understand KI perspective and experience regarding stakeholder engagement in systematic reviews. Although the nature of the discussions differed slightly according to the make-up of each interview group and the perspective and experiences of the KIs, each group reflected on the following overarching domains: (1) What did you expect/hope to achieve by engaging stakeholders? (2) What are some of the tangible benefits and challenges of stakeholder engagement (including points in the process when it is most/least valuable and particular types of stakeholders who have added the most/least value)? (3) How can we measure the value (i.e., the balance of benefits and challenges) of stakeholder engagement in systematic reviews?

Transcripts were entered into NVivo software for analysis. Two investigators and two research assistants read all of the transcripts to identify and synthesize recurring themes. Themes and findings were presented to the larger working group during biweekly calls to generate additional discussion and insights. In addition to identifying overarching themes, we conducted a more detailed exploratory analysis of the KI interviews with an eye towards articulating the benefits of engaging specific types of stakeholders at each phase of the systematic review. Finally, we noted any particular suggestions by KIs of how to measure the achievement of expected values or benefits.