# Introduction

## Background and Rationale

Medical research has evolved over the years from the paradigm of the lone research scientist to a model that encompasses a broader range of clinical research activities, including multidisciplinary team science. One of the more recent developments in this evolution is the active engagement of stakeholders in the selection, design, funding, and conduct of research. Activities to ensure engagement range from relatively simple approaches, such as asking stakeholders to participate in research meetings or comment on research proposals, to more resource intensive, including the use of Delphi techniques to reach consensus about research priorities and involving stakeholders directly making funding decisions or conducting research.1,2 The overarching goal of stakeholder engagement in medical research is to generate evidence that is more relevant and useful to those making real-world health care decisions, with the hope that this will increase the dissemination and uptake of research findings in clinical practice.3, 4

The move toward more explicit stakeholder engagement is consistent with the long tradition of applied research conducted to improve health and health care by the Agency for Healthcare Research and Quality (AHRQ). Along with other prominent institutions, such as the Patient-Centered Outcomes Research Institute, AHRQ Effective Health Care (EHC) Program firmly believes that stakeholder engagement is integral to its mission of providing evidence-based information to health care stakeholders that is timely, objective, scientifically rigorous, and developed and presented with transparency.5 The EHC Program defines a “stakeholder” as a person or group with a vested interest in a particular clinical decision and the evidence that supports that decision, including:

- Patients, caregivers, and patient advocacy organizations
- Clinicians and their professional associations
- Institutional health care providers, such as hospital systems and medical clinics
- Government agencies
- Purchasers and payers, such as employers and public and private insurers
- Health care industry representatives
- Health care policymakers at the Federal, State and local levels
- Health care researchers and research institutions.

A key component of the AHRQ EHC Program is to inform and facilitate medical decisions by producing systematic reviews that gather, evaluate, and synthesize the vast array of evidence on medical tests, treatments, and delivery systems.6 At present, the Evidence-based Practice Centers (EPCs) engage stakeholders at several distinct points throughout the lifecycle of a systematic review—from topic refinement through report dissemination (see Figure 1 below). Stakeholder engagement efforts in the EPC program initially focused on defining opportunities and developing materials to involve stakeholders in systematic reviews. Over time, the basic mechanics of working with stakeholders have become a routine part of the systematic review process, allowing the program to begin to explore how to improve stakeholder engagement and make it more effective.

Figure 1 AHRQ Effective Health Care Program: Points of stakeholder engagement for systematic reviews

This figure illustrates the purpose and mechanisms through which stakeholders are engaged at several distinct points throughout the lifecycle of a systematic review—from topic refinement through report dissemination. This figure offers three phases in which the EPC conducts systematic reviews with stakeholder engagement: Program Phase; Engagement Purpose; and Current Stakeholder Engagement Activities through AHRQ's EPC program. The program phase consists of topic development; topic refinement; research review; and research needs development. In the topic development process stakeholders help to clarify nomination and decisional dilemma and provide expert consultation as well as input on topic selection and topic prioritization. During the topic refinement process stakeholders help to clarify and refine key questions to accurately reflect the decisional issue and provide valuable input as key informants and technical experts. In the research review part of the process stakeholder engagement helps to provide clinical &methodological input to EPC's protocol and help with the composition of the team; conduct of the review; review the draft report and provide comments. The last part of the systematic review is research needs development, here stakeholders provide input to develop and prioritize research gaps and for all the reports stakeholders join in the composition of the team; review the draft report and provide comments on the report. For select reports stakeholders help with future research needs topic development.

Although there is a growing literature on the process of engaging stakeholders in medical research, there are a lack of clearly defined measures for reporting and evaluation, which limits the ability learn from past experience, understand the effectiveness of engagement, or identify what approaches work best.7 Indeed, knowing how to make an activity “more effective” presupposes an understanding of the desired outcome or expected benefit, and the ability to measure how effective the activity is to begin with. Moreover, understanding the challenges, tradeoffs, and adverse consequences of a particular activity is also integral to measuring overall impact and effectiveness.

Toward this end, this paper examines the benefits and challenges of engaging stakeholders in the process of developing and performing systematic reviews, drawing upon findings from the literature and Key Informant (KI) interviews with program leaders, systematic reviewers and stakeholders from within the EPC program and other international evidence-based programs. We define benefits as the expected positive changes to the quality and impact of the systematic review as a result of engaging stakeholders in the process. Additional positive externalities from engagement (i.e. positive consequences of the process that did not directly affect the quality and impact of the review such as building relationships, educating stakeholders about the research process, and personal benefits of involvement), were not included in the scope of this report. We define challenges as the costs and difficulties associated with engagement that need to be balanced against the benefits of involvement. Clearly defining the benefits and challenges involved in this process is an integral first step towards developing a process to measure and evaluate the impact of stakeholder engagement on the conduct, quality, and dissemination of the evidence reviews produced by AHRQ.