# Discussion

In general, findings from the KI interviews echoed the expected benefits of stakeholder engagement in systematic reviews highlighted in the small number of existing studies (see Table 1). For example, both the interviews and literature suggest that stakeholder engagement helps to improve the relevance and quality of the review and has the potential to increase dissemination and uptake of the report findings. However, KIs placed additional emphasis on the importance of stakeholder engagement for establishing credibility and buy-in, anticipating controversy, and ensuring programmatic and societal accountability. With respect to challenges, both the literature and the KI interviews emphasized the extra time and resources necessary to engage stakeholders and the need for appropriate training (on the part of stakeholders and researchers alike) in order to maximize the benefit of engagement.

Although the general themes highlighted in the literature and the KI interviews were similar, the interviews provided a more nuanced understanding of the tradeoffs involved, including the variation in relative benefits and challenges depending on who is engaged and when they are engaged. Systematic reviewers in particular highlighted the importance of engaging the right stakeholder at the right time and explained that in their experience the benefit of engagement often depends on the characteristics of the individual stakeholder, or combination of stakeholders, involved (e.g., training, personal experience, personality traits, level of connection with others). Many of the discussions also focused on the challenge of deciding what input to incorporate into the report, and the inability to respond to all stakeholder comments and/or concerns.

Moreover, a number of systematic reviewers clearly identified the need for more differentiated thinking about specific types of stakeholders (i.e., the general public is different than patients who are different from patient advocacy groups) as well as which stakeholders can contribute unique and valuable perspectives at specific points in the systematic review process. Overall, one of the strongest messages from the systematic reviewers we interviewed was the importance of linking the benefits of engaging specific types of stakeholders at different stages of the review process, rather than rotely engaging a broad range of stakeholders in all phases of the review as “insurance.”

While KI interviews conducted for this project were designed primarily to understand the overarching expected benefits of engaging stakeholders, in some cases they provided explicit examples of the benefits of particular stakeholders at specific points in the review. This enabled us to conduct a more refined exploratory analysis of the interviews, coding relevant comments from KIs about the specific benefits and challenges of engaging different types of stakeholders at different stages in the systematic review. Using a matrix (see Appendix E for example), we coded comments about the value of engaging the eight different categories of stakeholders (described on p.1 of the report) across three program phases for systematic reviews: topic refinement, research conduct, and research needs development. Of all phases of the systematic review we considered, the formative phase of refining the topic and developing the key questions was repeatedly identified as the most critical point for engaging stakeholders in general, and certain groups of stakeholders in particular. It was also the only phase where KIs felt engaging stakeholders produced all six benefits: credibility, anticipating controversy, transparency and accountability, relevance, quality, and dissemination and uptake of systematic review findings. In addition, KIs felt every category of stakeholder should be engaged at this stage. Future research could utilize such a matrix to explore in detail the expected benefits of engaging different types of stakeholders in each phase of the review.