# Conclusions and Future Directions

Although it is recognized by many as an important next step, to date there have been few efforts to measure the benefits/tradeoffs of specific stakeholder engagement processes or differing approaches to selecting and engaging differing stakeholder types. In order to refine our processes for efficiently and effectively engaging stakeholders, we need to develop methods to evaluate the impact of stakeholder engagement based on a more concrete understanding of the specific benefits we are hoping to achieve. Towards this end, we reviewed the existing literature and conducted a series of KI interviews in an effort to more explicitly define the expected benefits of engaging stakeholders in systematic reviews.

Through our interviews, we identified six main expected benefits and five primary challenges of involving stakeholders in systematic reviews. Of note is that all benefits relate (either directly or indirectly) to the systematic review product, whereas most of the challenges relate to the process of eliciting meaningful stakeholder input. This suggests that attempts to measure stakeholder impact need to include both process and outcome measures.

Six main categories of expected benefits
1. Establishing credibility
2. Anticipating controversy
3. Ensuring transparency and accountability
4. Improving relevance
5. Enhancing quality
6. Increasing dissemination and uptake of systematic review findings.

Five primary challenges
1. Time and resources
2. Researcher skills for stakeholder engagement
3. Finding the right people
4. Balancing multiple inputs
5. Understanding the best/most appropriate time in the review process to engage different types of stakeholders.

Of all phases of the systematic review, the topic refinement and research development phase was repeatedly identified as the point where stakeholder engagement yielded the greatest benefit, with a preponderance of comments on the importance of stakeholder engagement at this phase in order to get buy-in and credibility for the process and product, to ensure the systematic review was scientifically valid, relevant, and useful, and to ensure uptake and use of the products. After verifying the appropriateness of this set of benefits to the EPC program, the next step in evaluating stakeholder engagement activities is to identify concrete measures for each of these benefits and challenges that can be used to assess the effectiveness of different methods, timing and intensity of stakeholder engagement.