# Key Informants

- Eric Bass, M.D., M.P.H.
  Director
  Johns Hopkins Evidence-based Practice Center
  Baltimore, MD
- Suzanne Belinson, Ph.D., M.P.H.
  Associate Director
  Blue Cross Blue Shield Association, Technology Evaluation Center
  Chicago, IL
- Laurence Clark, M.D., F.A.C.P., C.M.D.
  Medicare Medical DirectorEast
  Syracuse, NY
- Pam Curtis, M.S.
  Deputy Director
  Center for Evidence-based Policy, Oregon
  Health and Science University
  Portland, OR
- Kay Dickersin, Ph.D.
  Director
  Center for Clinical Trials, Johns Hopkins
  Center for Global Health
  Baltimore, MD
- Donna Dryden, Ph.D.
  Associate Director
  Alberta Evidence-based Practice Center
  Alberta, Canada
- Rachael Fleurence, Ph.D.
  Acting Director
  Patient-Centered Outcomes Research
  Methods, Patient-Centered Outcomes
  Research Institute
  Washington, DC
- Laura Fochtmann, M.D.
  Medical Editor
  American Psychiatric Association Practice Guidelines
  Stony Brook, NY
- Jessie Gruman, Ph.D.
  President and Founder
  Center for Advancing Health
  Washington, DC
- Lisa Hartling, B.Sc.P.T., M.Sc.
  Director
  Alberta Evidence-based Practice Center
  Alberta, Canada
- Robert Kane, M.D.
  Director
  Minnesota Evidence-based Practice Center
  Alberta, Canada
- Michael LeFevre, M.D., M.S.P.H.
  Co-Vice Chair
  U.S. Preventive Services Task Force
  Columbia, MO
- Margaret Maglione, M.P.P., B.A.
  Associate Director
  RAND Southern California Evidence-based Practice Center
  Santa Monica, CA
- Marian McDonagh, Pharm.D.
  Associate Director
  Pacific Northwest Evidence-based Practice Center
  Portland, OR
- Brendan McIntosh, M.Sc.
  Clinical Research Officer
  Canadian Agency for Drugs and Technologies in Health
  Ottawa, ON, Canada
- Melissa McPheeters, Ph.D., M.P.H.
  Director
  Vanderbilt Evidence-based Practice Center
  Nashville, TN
- Evan Myers, M.D., M.P.H.
  Chief of the Division of Clinical and Epidemiological Research
  Duke University School of Medicine
  Durham, NC
- Hussein Noorani, M.S.
  Senior Scientist
  Blue Cross Blue Shield Association, Technology Evaluation Center
  Chicago, IL
- Ileana Piña, M.D., M.P.H., F.A.H.A., FACC
  Executive Council and Care Standards Committee
  Heart Failure Society of America
  Bronx, NY
- Karen Robinson, Ph.D.
  Co-Director
  Johns Hopkins Evidence-based Practice Center
  Baltimore, MD
- Karen Schoelles, M.D., S.M., F.A.C.P.
  Director
  ECRI Institute-Penn Medicine Evidence-based Practice Center
  Philadelphia, PA
- Joanna Siegel, R.N., S.M., S.D.
  Community Forum
  Center for Outcomes and Evidence, Agency for Healthcare Research and Quality
  Rockville, MD
- Jean Slutsky, P.A., M.S.P.H.
  Director
  Center for Outcomes and Evidence, Agency for Healthcare Research and Quality
  Rockville, MD
- Sophie Staniszewska, Ph.D.
  Patient and Public Involvement and Patient Experiences
  RCN Research Institute, Warwick Medical School
  Coventry, United Kingdom
- Paddy Storrie
  Technology Appraisal Committee
  National Institute for Health and Clinical Excellence
  Harpenden, United Kingdom
- Mitchell Sugarman, M.B.A.
  Vice President of Health Economics, Policy and Payment
  Medtronic Cardiac and Vascular Group
  Santa Rosa, CA
- Thomas Trikalinos, M.D.
  Director
  Brown University Center for Evidence-based Medicine
  Providence, RI
- Craig Umscheid, M.D., M.S.
  Senior Associate Director
  ECRI Institute-Penn Medicine Evidence-based Practice Center
  Philadelphia, PA
- Meera Viswanathan, Ph.D.
  Director
  RTI International-University of North
  Carolina at Chapel Hill Evidence-based Practice Center
  Chapel Hill, NC
- Renee Wilson, M.S.
  Senior Project Manager
  Johns Hopkins Evidence-based Practice Center
  Baltimore, MD
- Durhane Wong-Rieger, Ph.D., M.A.
  President and CEO
  Institute for Optimizing Health Outcomes
  Toronto, Canada
- Judy Zerzan, M.D., M.P.H.
  Colorado Department of Health Care Policy and Financing
  Aurora, CO