# Key Information Perspectives on Benefits of Specific Types of Stakeholder Engagement in the Topic Refinement Phase

| | | Expected Benefit of Stakeholder Engagement in Systematic Reviews
| Buy-in Process / Credibility | Systematic Review (Relevant and Useful) | Uptake and Use of Product | Political - Controversy Mitigation | Programmatic Needs/Social Accountability
SYSTEMATIC REVIEW PHASES
Topic Refinement; Research Plan (PICOTS, I/E Criteria) | Patients, caregivers and patient advocacy organizations, Clinicians and their professional associations, Institutional health care providers, such as hospital systems and medical clinics, Government agencies, Purchasers and payers, such as employers and public and private insurers, Health care industry representatives, Health care policy makers at Federal, State and local levels | Clinicians and their professional associations, Government agencies, Health care policymakers at the Federal, State and local levels, Health care researchers and research institutions | Patients, caregivers and advocacy organizations, Clinicians and their professional associations, Government agencies, Purchasers and payers, such as employers and public and private insurers, Health care policy makers at Federal, State and local levels | Patients, caregivers, and patient advocacy organizations, Clinicians and their professional associations, Government agencies, Health care industry representatives, Health care policymakers at the Federal, State and local levels, Health care researchers and research institutions | Patients, caregivers, and patient advocacy organizations, Clinicians and their professional associations, Government agencies, Health care policymakers at the Federal, State and local levels, Health care researchers and research institutions

Note: I/E=Inclusion/exclusion; PICOTS=Population, Intervention, Comparator, Outcome, Timing, Setting