# Select Quotes From Key Informant Discussions

Expected Benefits of Engaging Stakeholder in Systematic Reviews
Establishing credibility and buy-in to the systematic review process
“I think that we were looking for buy-in from the beginning, the sense that the stakeholders felt that they were involved in a process, not just being announced to at the end what the result was, that they at least had an opportunity to review and provide input into the way the review was being done.”
“It's partly buy-in to the process itself . Although the goals of the reporting is to be as transparent as possible there can always be questioning of the reporting . So if people have been involved from the beginning in conference calls and reviewing various documents and we're able to document that that's at least been addressed, that can, again, maybe not totally prevent any subsequent controversy that was mitigated.”
Producing reports that are scientifically valid, relevant, and useful
“So I think framing of the issue and the questions at the beginning is one of the absolutely most important things the patients can do for us . It makes it more relevant.”
“We have certainly seen stakeholders fundamentally change our key questions based on their input, and so clearly they're having an impact, particularly in that process of framing what the true important questions are . We talk to them about decisional dilemmas and helping us understand where the points are in a medical care process that they truly are at sort of a crossroads and would benefit from specific information.”
“They are incredibly important for understanding how a report needs to be set up and to make sure that it isn't sort of an ivory tower exercise but is useful and usable at the end of the day.”
“We need to know in advance what the most important questions and issues are to people who are in the field who are actually going to be using the results; whether it's parents trying to decide what the best interventions are for their kids; whether it's surgeons trying to decide what procedures…”
“[Stakeholder input was valuable in elucidating]…some of the nuances around those key questions, and I guess the example I'm thinking of was in perhaps a more clear definition of the population, and then certainly discussions around some of the outcomes.”
“We've certainly heard examples in cardiovascular disease of a research team that was very focused on laboratory value outcomes, and the patient says, “You know that's not the issue…the issue s I that I am really tired . I am just so exhausted.” You've got to get these sorts of quality of life outcomes . And that's critical . It is absolutely critical.”
“I have seen the inclusion of patients and patient advocates in the formulation of the questions be critically important in shaping, in very nuanced ways, the questions and the sub-questions, the overall quality of the review and also the utility of the review when it is actually completed.”
“…when thinking of how stakeholders have really changed the direction of projects the first examples that popped into my mind are examples where they've helped us understand where tests and devices and imaging protocols that were potentially within the scope of the review were absolutely obsolete and so did not need to be evaluated.”
Anticipating and mitigating controversy/political issues
“… [F]or some topics that we knew in advance were going to be somewhat controversial… I think there's a benefit in having some of the anticipated critical voices . The voices will be critical after the report … at least have some say or some stake in the report itself . So getting them involved upfront hasavoided all controversy but it certainly has helped us be prepared for what's to come.”
“We just did a large report for an area that was quite controversial and that only became clear to us really at the end, and it was unfortunate because I thought, gee, if I'd known this or had this context or background at the outset, and I think that … could have provided that and maybe we just weren't asking the right questions because we didn't know what questions to ask, or how to involve them best.”
“I think the only thing I would add is that involving them earlier on helps them being people that we feel might have conflicting views or controversial views . Including them earlier on might get some sense of, ownership is probably too strong a word, but sense of involvement early on that they provided input . Also at the end, I think, for us there's often the sense of the peer review process of let's make sure we get people involved, or at least a couple of people involved that we think might have issues with this report . I'd rather hear of those issues and controversies during the peer review process then after.”
“The mammography recommendation accelerated what was, to be perfectly honest, almost a backburner movement. We aspired to increasing the transparency of the process and we were considering ways to do so, but after mammography we said, “Okay, this now has to be a high priority.”
Facilitating dissemination and uptake of report findings
“The main thing is to make sure that the report is being used at the end and not just sitting on a shelf.”
“Perhaps [stakeholders] not being there in the same way I'd sort of feel nervous about the impact it would have in the outer world, because it's not something that's been developed with the insights of people out in the big wide world . It would be a bit like working in a laboratory in a very isolated way, which I certainly would like because I wouldn't have the sort of touch point for the relevance of this piece of work, or its acceptability, or its appropriateness.”
“I think with the involvement of the public can actually direct our research in much more useful ways, that you're doing something that benefits society as a whole and that is going to be more useful to people out there.”
“We're not seeing a whole lot of evidence that systematic reviews are actually being used in a way that actually makes a difference in terms of our health care…”
“Transparency facilitating dissemination and uptake and impact are critical in terms of ensuring that we have the key perspectives on the report and providing feedback on the review . At the end of the day by having the key perspectives present to ensure that we will disseminate the report to an appropriate audience and the key audiences, and that will also ensure that we have uptake and impact.”
“We think about including them in the reviews because of the implementation aspect afterwards . So are we including people that will actually be able to help us disseminate the research once the research has been done? So I think that's another aspect of why we'd want to be engaging stakeholder in the process.”
“Even the scientific community, I think, needs to be more aware of the EPC program, the reviews that are being conducted, the way they are conducted, the output from those reviews . So I think that by engaging a broader array of people at the beginning of the process, I'm imagining that that could have important impact on consumption of that evidence when it comes out . I think that people don't even know about this EPC program.”
Ensuring programmatic and societal accountability
“Research is often funded by taxpayers and as a taxpayer I would prefer research to be undertaken that has a relevance to my life.”
“…with finite resources there is an argument for democratic accountability for that money…I think for me it is not just the money, it's feeling that you're doing something that benefits society as a whole.”
Challenges of Engaging Stakeholder in Systematic Reviews
Time and resources
“It is time consuming.”
“There is a lot of commitment required from stakeholders.”
“Engaging stakeholders uses resources.”
“Time . I think more than anything else, time . You basically add 1 to 3 months at every step in which you choose to engage in outside resources and call them stakeholders. “
Lack of training
“Stakeholders need to be educated before they can effectively participate.”
“The scope of the review can be broadened by stakeholders.”
Finding the right people
“I think it is not only who the stakeholders represent, for example if you're thinking about your needs for various clinical experts to have the right experts whether it's a surgeon or a hospitalist, or an oncologist, or radiologist, but it's also about who those individuals actually are….do they have the right personal characteristics where they are responsive, professional, diplomatic….and then do they have the right connections? Are they part of important societies or in leadership roles in various societies and can spread the word? One radiologist is not the same as another radiologist, although that might be a starting point.”
“…also individuals may choose to join such a process because they have their own personal agenda, and when that's present many of us have found that that can totally derail the group process and the ability to really look at things objectively.”
“We patients are a very varied bunch and I know it takes a lot of guts and a lot of commitment to actually invite us to participate meaningfully in the development; both of the question that the systematic review is going to ask or the questions, and also, to participate as a working member of the group assuming that our work will not rise to the quality of someone who really has the methodological rigor and background to apply the rigor that's needed.”
“And some of those characteristics are training, which probably is highly associated with how effective you're going to be . So you know do they have a good foundation of clinical epi(demiology) and critical appraisal and the development of research questions, you know relevant outcomes as opposed to not so relevant outcomes.”
“I would say that I think particularly now there's a lot more interest in the part of a small group of patients partly stimulated by the query to be willing to participate in the development of systematic reviews, but I think that the preparation of investigators and the preparedness of investigators to put the time and effort in to making that participation meaningful is sadly lacking.”
Knowing who to engage when
“I think this has been sort of a challenge here in the US . In particular I think we went on, in recent, years, sort of a rampage of all stakeholders all the time should be engaged at the table as investigators in every research project . That was sort of the message that was coming from some of the funding agencies, and I think the feeling among some of the researchers was that not only is that not always true or helpful but it devalues the particular roles of the stakeholders.”
“The topic of this project, the value of stakeholder engagement, as if they're all one group of people who all represent the same thing and they're certainly not . I think we are really at a point in understanding this process that we need to move in to something that's much more nuanced.”
Balancing multiple inputs
“The other issue is that once they express an opinion you have to deal with it . It depends very much on the skills and the personality of the people running the project . I did a number of projects where we had incredibly accepting project leaders who basically because somebody said it they decided they would go off and do it even though it wasn't the best idea in the world . Part of my role is to try and rein in, not chasing down every alleyway that somebody recommends.”
“The flip side of that, which I think is quite problematic, is it can put an individual patient in a position where they feel massively uncomfortable . That they feel somehow that the approval or disapproval of the treatment is going to be down to them and how well they speak and how good a case they put . I think that's really troubling that people go away with that feeling or enter with that feeling when in fact they're much more peripheral to the decision process than that.”
“There are other cases where the patient who is present….says what they think the committee needs to hear…and not what they are genuinely are experiencing.”
“You also get patients coming to speak who are complete outliers to the general experience of patients on that treatment . For instance, you might have a 7-month average life expectancy but the patient speaking to you is the person who has actually lived 5years on the treatment . The benefit of their voice is a little bit lost because they don't fairly characterize that particular stakeholder group.”
Evaluate against real world outcomes
“I think that, once again, we do need to evaluate the value of stakeholder participation in systematic reviews against some real world outcomes, even if it's just page views on articles . Just saying that, like I did before, oh the questions are improved, it's just going to cut it . It's too self-preferential, too proximal.”
“…and that's just not good enough to say, oh well, we met with the chair six times and the stakeholders were satisfied . No, no, no, no – I mean it really is the quality of the product that's produced and the impact that that has; whether it's just the number of people who've read it, where it gets picked up . I know that you can't trace whether it gets implemented into practice, God forbid, but it's got to be bigger than that kind of self-serving, easy to score an A on evaluation participation.”
Changes in key questions and other aspects of the report
“When I think about it, we're not very good about tracking the changes in the questions, for example, which could help us address that question I think . That's actually tedious to do.”
“For those EPCs that would have the records; I would think that you could at least look at what the initial PICOTs and key questions may be . How did the protocol change from the one originally written by the EPC to the one that was finally in the report?”
“I wonder if there'd be a way to take a particular report where there have been some drastic changes and look at, say, how many papers would have been included—did it improve the efficiency of the search, or would certain situations have been left out if there hadn't been input from the stakeholders . I think you'd have to look at things like number citations, type of studies, particular patient populations.”
“Really, the outcomes would be many things, what the key questions were, what the PICOTs were, what the inclusions criteria were, what the results of—just the count of how many studies were accepted one way versus the other, and what the final conclusions were and how they differed.”
Qualitative evaluation/survey of stakeholders
“I would say you would go back and interview . Probably the ones that are used for guidelines aren't the best example of this, but you could go back and talk to your initial stakeholders and ask them if they used it for anything, and if so, for what.”
“I was going to say in addition to looking at the conclusions differed or the results differed, you could have policymakers or that sort of person review and see which one was actually more informative.”
“Another thing I think that would really help you judge whether the key informant or stakeholder input was important was longitudinally the end use of the report and how many groups used it and what they used it for . That would involve some interviews or focus groups well after the final report.”

Note: EPC=Evidence-based Practice Center; PICOTS=Population, Intervention, Comparator, Outcome, Timing, Setting