# Interview Guides

## Introduction

- The mission of the Agency for Healthcare Research and Quality's (AHRQ) Effective Health Care (EHC) Program is to provide evidence-based information for health care stakeholders.
- The EHC seeks to produce information that is relevant to stakeholder needs, timely, objective, scientifically rigorous in construct, and developed and presented with transparency.
- AHRQ engages stakeholders in all facets of their research enterprise, including the production of systematic reviews, with the goal of ensuring that research findings reflect the needs of diverse users, are relevant to their unique challenges, and are applicable in real-world situations.

## Purpose of discussion sessions

- The objective of our project is to better understand the value of stakeholder engagement in the production of quality systematic reviews so that we can evaluate and improve how we work with stakeholders in the future .
- Our primary goals are to:
  1. articulate the expected societal benefits of engaging stakeholders in systematic reviews;
  2. understand how we would measure the effectiveness of stakeholder engagement; and
  3. understand when we would measure the effectiveness of stakeholder engagement .
- We are very interested in learning from your experience engaging stakeholders or being engaged as a stakeholder in a systematic review .
- There are no right or wrong answers, so please feel free to share your thoughts openly . We strive for a balanced opportunity for everyone to express their thoughts during the discussion session call .
- We would welcome any materials that you would like to share with us either before or after the discussion session. Please send any materials to Johanna.anderson2@va.gov.

## Ground rules for discussion sessions

- The discussion session proceedings will be tape recorded, transcribed, and analyzed for themes .
- Although the final report may list individuals who were interviewed, your individual responses will remain anonymous . Any material from the discussion session that is used in the final report will be de-identified so that it cannot be linked to specific individuals or organizations .
- You may refrain from answering any questions and are welcome to leave the discussion at any time .
- Any questions before we begin?

## Discussion Session Guide (Systematic Review/Programmatic Perspective)

### Introductory/framing questions

1. What types of stakeholders (e.g., clinical experts, patients, patient representatives) do you typically engage in the systematic review (SR) process?
2. In what aspects of the SR process have you typically involved stakeholders (e.g., developing key questions, providing feedback on protocol, etc.)? Does the type of stakeholder vary depending on the stage of the review process?

### Understanding the value of engaging stakeholders in systematic reviews

3 What were the key factors that prompted you to include stakeholders (i.e. mandates, research improvement, other)?
4 What were your expectations about engaging stakeholders? What did you expect to get from engaging them in your systematic reviews?
5 In your experience, how does the review process differ when stakeholders are actively engaged?
6 Can you describe the tangible benefits you've seen from engaging stakeholders?
  a. Are there points in the review process when it is most beneficial to engage stakeholders?
    i. If yes, what are the tangible benefits?
  b. Is there a certain type of stakeholder that is most appropriate for engagement in systematic reviews? (Are there certain types of stakeholders that you have deliberately included or excluded?)
    i. If yes, when in the process do you get the most benefit from engaging this type of stakeholder?
7 What are the primary challenges or costs of engaging stakeholders?
  a. Is there a point in the review process when engagement is particularly challenging?
  b. Are there certain types of stakeholders that are harder to engage than others?
8 Have you conducted any type of formal or informal assessment of the benefits and costs of engaging stakeholders?
  a. If yes, can you tell us what that looked like?

### Closing questions/wrap-up

9 What (in your experience) is lost by not engaging stakeholders?
  a. Are you aware of any publications that address this issue?
10 Are there any additional issues we didn't cover today that you think are important in understanding the value of involving stakeholders in the systematic review process?

## Discussion Session Guide (Stakeholder Perspective)

### Introductory/framing questions

1. Have you been involved as a stakeholder in the systematic review process? If so, please describe your experience, including what role you played and who was part of the team (including other stakeholders).

### Understanding the value of engaging stakeholders in systematic reviews

2 What were the key factors that prompted you to participate? What were your expectations of your role in the systematic review process? What did you expect to get out of this process?
3 Do you feel that you made a contribution to the systematic review process? If so, how?
4 In your experience, is the review process different when stakeholders are actively engaged? Can you give me some specific examples of how it is different?
5 Do you think you were involved at the right stage? Do you think your input would have been more useful if you had been involved either earlier or later in the research process?
6 Did you encounter any challenges or barriers? If yes, can you tell me what was challenging?
7 What type of stakeholder do you think is most important to engage in systematic reviews?
  a. When in the systematic review process should this type of stakeholder be involved?

### Closing questions/wrap-up

8 What (in your experience) is lost by not engaging stakeholders?
  a. Are you aware of any publications that address this issue?
9 Are there any additional issues we didn't cover today that you think are important in understanding the value of involving stakeholders in the systematic review process?

If you have any additional comments or materials you wish to share, such as examples of reviews, please let us know via telephone at 503-220-8262 x52384 or via email at Johanna.anderson2@va.gov. We appreciate any and all information you can provide us with.