# Relevant Information From Literature Search

Table B-1 Context of stakeholder engagement

Table B-2 Stakeholder identification

Table B-3 Tangible benefits of stakeholder engagement

Table B-4 Tangible challenges of stakeholder engagement

Table B-5 Measurement of stakeholder engagement

## Appendix B References

1 Horey D. Consumer Involvement in The Cochrane Collaboration. Presented at The Cochrane Collaboration's Mid-Year Strategic Meeting. Auckland AUS. 2010. http://consumers.cochrane.org/sites/consumers.cochrane.org/files/uploads/Consumer%20Involvement%20in%20the%20Cochrane%20Collaboration%20Background%20paper.pdf. January 2013.
2 Nilsen ES, Myrhaug HT, Johansen M, et al. Methods of consumer involvement in developing healthcare policy and research, clinical practice guidelines and patient information material. Cochrane Database of Systematic Reviews. 2006;3:CD004563. [pmid: 16856050].
3 Wale J, Colombo C, Belizan M, et al. International health consumers in the Cochrane Collaboration: fifteen years on. J Ambul Care Manage. 2010;33(3):182-9. [pmid: 20539144].
4 Curtis P, Slaughter-Mason S, Thielke A, et al. PCORI Expert Interviews Project: Final Report. Center for Evidence-based Policy, Oregon Health & Science University. Portland, OR. 2012. http://pcori.org/assets/pdfs/Expert%20Interviews%20Part%201.pdf. January 2013.
5 Deverka PA, Lavallee DC, Desai PJ, et al. Stakeholder participation in comparative effectiveness research: defining a framework for effective engagement. J Comp Eff Res. 2012;1(2):181-94. [pmid: 22707880].
6 Domecq Garces JP, Prutsky Lopez GJ, Wang Z, et al. Eliciting Patient Perspective in Patient-Centered Outcomes Research: A Meta Narrative Systematic Review. 2012.
7 Hoffman A, Montgomery R, Aubry W, et al. How best to engage patients, doctors, and other stakeholders in designing comparative effectiveness studies. Health Aff (Millwood). Oct. 2010;29(10):1834-41. [pmid: 20921483].
8 Kreis J, Puhan MA, Schunemann HJ, et al. Consumer involvement in systematic reviews of comparative effectiveness research. Health Expect. Dec. 2013;16(4):323-37. [pmid: 22390732].
9 Gagnon MP, Desmartis M, Lepage-Savary Ds, et al. Introducing patients' and the public's perspectives to health technology assessment: A systematic review of international experiences. Int J Technol Assess Health Care. 2011;27(1):31-42. [pmid: 21262085].
10 Gauvin FP, Abelson J, Giacomini M, et al. “It all depends”: Conceptualizing public involvement in the context of health technology assessment agencies. Soc Sci Med. 2010;70(10):1518-26. [pmid: 20207061].
11 Hailey D. Consumer involvement in health technology assessment (Structured abstract). Health Technology Assessment Database. Alberta Heritage Foundation for Medical.
12 Hailey D, Werko S, Bakri R, et al. Involvement of consumers in health technology assessment activities by Inahta Agencies. Int J Technol Assess Health Care. Jan. 2013;29(1):79-83. [pmid: 23217279].
13 Moran R, Davidson P. An uneven spread: A review of public involvement in the National Institute of Health Research's Health Technology Assessment program. Int J Technol Assess Health Care. 2011;27(4):343-7. [pmid: 22004775].
14 Nielsen CP, Lauritsen SW, Kristensen FB, et al. Involving stakeholders and developing a policy for stakeholder involvement in the European network for health technology assessment, EUnetHTA. Int J Technol Assess Health Care. Suppl 2. 2009;25:84-91. [pmid: 20030895].
15 Oliver S, Clarke-Jones L, Rees R, et al. Involving consumers in research and development agenda setting for the NHS: developing an evidence-based approach (Structured abstract). Health Technol Assess. Apr. 2004;8(15):1-148. III. IV. [pmid: 15080866].
16 Barber R, Boote JD, Parry GD, et al. Can the impact of public involvement on research be evaluated? A mixed methods study. Health Expect. 2012;15(3):229-41. [pmid: 21324054].
17 Boote J, Barber R, Cooper C. Principles and indicators of successful consumer involvement in NHS research: results of a Delphi study and subgroup analysis. Health Policy. Feb. 2006;75(3):280-97. [pmid: 15899535].
18 Boote J, Baird W, Sutton A. Involving the public in systematic reviews: a narrative review of organisational approaches and eight case examples. J Comp Eff Res. 2012;1(5):409-20. [pmid: 24236418].
19 Brett J, Staniszewska S, Mockford C, et al. The PIRICOM Study: A systematic review of the conceptualisation, measurement, impact and outcomes of patients and public involvement in health and social care research. 2010. http://www.google.com/url?sa=t&rct=j&q=piricom%20study%20a%20systematic%20review%20of%20the%20conceptualisation&source=web&cd=1&ved=0CDQQFjAA&url=http%3A%2F%2Fwww.ukcrc.org%2Findex.aspx%3Fo%3D3234&ei=9PfUULL2A6X02wWSw4D4AQ&usg=AFQjCNGeFVKDQJTKheuYKHuPuS8c4UlpPw&bvm=bv.1355534169,d.b2I. January 2013.
20 Brett J, Staniszewska S, Mockford C, et al. Mapping the impact of patient and public involvement on health and social care research: a systematic review. Health Expect. 2012. Jul. 19.
21 National Institute for Health Research. Public involvement in systematic reviews: Supplement to the briefing notes for researchers. INVOLVE. Eastleigh, UK. 2012. http://www.invo.org.uk/wp-content/uploads/2012/10/INVOLVEPublicInvolvementSystematicReviews2012.pdf. January 2013.
22 Keown K, Van Eerd D, Irvin E. Stakeholder engagement opportunities in systematic reviews: Knowledge transfer for policy and practice. J Contin Educ Health Prof. 2008;28(2):67-72. [pmid: 18521874].
23 Vale CL, Thompson LC, Murphy C, et al. Involvement of consumers in studies run by the Medical Research Council Clinical Trials Unit: results of a survey. Trials. Jan. 13. 2012;13:9. [pmid: 22243649].
24 Wright D, Foster C, Amir Z, et al. Critical appraisal guidelines for assessing the quality and impact of user involvement in research. Health Expect. 2010;13(4):359-68. [pmid: 20629767].
25 Guarino P, Elbourne D, Carpenter J, et al. Consumer involvement in consent document development: a multicenter cluster randomized trial to assess study participants' understanding. Clinical Trials. February. 1. 2006;3(1):19-30. [pmid: 16539087].
26 Angell KL, Kreshka MA, McCoy R, et al. Psychosocial intervention for rural women with breast cancer: The Sierra-Stanford Partnership. J Gen Intern Med. 2003;18(7):499-507. [pmid: 12848832].
27 Popay J. What are the impacts of user involvement in health and social care research and how can they be measured?. Medical Research Council. 2012. http://www.mrc.ac.uk/ResearchPortfolio/Grant/Record.htm?GrantRef=G0902155&CaseId=16504. February 2013.