# Search Strategy

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to January Week 1 2013,

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 14, 2013

Date searched: 01/15/2013

1 | ((stakeholder$ or consumer$ or community or user$ or public) adj2 (engag$ or involv$) adj5 (review$ or meta analys$ or metaanalys$)).ti,ab. | 80
2 | exp consumer participation/ | 29386
3 | exp comparative effectiveness research/ or exp review literature as topic/ or exp meta-analysis as topic/ | 18744
4 | 2 and 3 | 74
5 | 1 or 4 | 153

EBM Reviews - Cochrane Database of Systematic Reviews 2005 to November 2012

Date searched: 01/15/2013

1 | ((stakeholder$ or consumer$ or community or user$ or public) adj2 (engag$ or involv$) adj5 (review* or meta analys$ or metaanalys$)).ti,ab. | 0

EBM Reviews - Cochrane Methodology Register 3rd Quarter 2012

Date searched: 01/15/2013

1 | ((stakeholder$ or consumer$ or community or user$ or public) adj2 (engag$ or involv$) adj5 (review* or meta analys$ or metaanalys$)).ti,ab. | 12

EBM Reviews - Database of Abstracts of Reviews of Effects 4th Quarter 2012

Date searched: 01/15/2013

1 | ((stakeholder$ or consumer$ or community or user$ or public) adj2 (engag$ or involv$) adj5 (review* or meta analys$ or metaanalys$)).ti,ab. | 0

EBM Reviews - Health Technology Assessment 4th Quarter 2012

Date searched: 01/15/2013

1 | ((stakeholder$ or consumer$ or community or user$ or public) adj2 (engag$ or involv$)).ti. | 3

Scopus

Date searched: 01/15/2013

1 | (stakeholder* or consumer* or community or user* or public) W/5 (engag* or involve*) W/5 (review* or meta-analys* or metaanalys*)TITLE ABSTRACT
2 | Not participatory | 139